# 8 REFERENCES

* Cited in text

*Abrams J. 1980. Nitrate tolerance and dependence. American Heart Journal 99:113–123.6766045
*ACGIH. 1994. Threshold limit values for chemical substances and physical agents and biological exposure indices for 1994-1995. American Conference of Governmental Industrial Hygienists. Cincinnati, OH.
*Anderson D, Styles JA. 1978. Appendix 2: The bacterial mutation test. Br J Cancer 37:924:930.354673
*Andersson K, Levin JO, Nilsson CA. 1983. Evaluation of solid sorbents for sampling aliphatic and aromatic nitro compounds. Chemosphere 12:377–384.
Army. 1979. Problem definition study on 1,3-dinitrobenzene, I,3,5 trinitrobenzene, and di-n-propyl adipate. Contract no. DAMD17-77-C-7057. Frederick, MD: U.S. Army Medical Research and Development Command, Fort Detrick. Document no. AD A099732.
*Army. 1981. Preliminary pollutant values for Alabama Army Ammunition Plant. Frederick, MD: U.S. Army Medical Research and Development Command, Fort Detrick. Document no. AD 104203.
Army. 1982. Microbial interactions with several munitions compounds: 1,3-Dinitrobenzene, 1,3,%initrobenzene, and 3,5-trinitroaniline. Frederick, MD: U.S. Army Medical Research and Development Command, Fort Detrick. Document no. AD Al 16651.
*Army. 1983. HPLC analysis of SEX, HMX, TAX, RDX and TNT in wastewater. Frederick, MD: U.S. Army Bioengineering Research and Development Laboratory, Fort Detrick. Document no. AD A127348.
Army. 1984a. Basic mechanisms of explosive compounds in wastewater. Contract no. DAAKll-83-C-0006. Aberdeen Proving Ground, MD: U.S. Army Toxic and Hazardous Materials Agency. Document no. AD A141703.
*Army. 1984b. Database assessment of health and environmental effects of munition production waste products. Contract no. DE-AC05-849R21400. Frederick, MD: U.S. Army Medical Research and Development Command, Fort Detrick. Document no. AD A145417.
*Army. 1985a. Comparison of extraction techniques and solvents for explosive residues in soil. Order no. Al-5-ROOOl-XX-Al-48. Aberdeen Proving Ground, MD: U.S. Army Toxic and Hazardous Materials Agency. Document no. AD A2205888.
Army. 1985b. Carcinogenesis of nitrated toluenes and benzenes, skin and lung tumor assays in mice. Contract no. DE-AC05-840R21400. Frederick, MD: U.S. Army Medical Research and Development Command, Fort Detrick. Document no. DE 85012081.
*Army. 1986. Liquid and gas chromatographic determination of 1,3,5trinitrobenzene in water. Frederick, MD: U.S. Army Medical Research and Development Command, Fort Detrick. Document no. AD A167746.
Army. 1987a. Development of an analytical method for explosives residues in soil. Aberdeen Proving Ground, MD: U.S. Army Toxic and Hazardous Materials Agency. Document no. AD Al 83738.
*Army. 1987b. Conventional weapons demilitarization: A health and environmental effects database assessment. Project order no. 83 PP3818. Frederick, MD: U.S. Army Medical Research and Development Command, Fort Detrick. Document no. AD A2205888.
*Army. 1988. Residual explosives criteria for treatment of Area P soil, Louisiana Army Ammunition Plant. Frederick, MD: U.S. Army Biomedical Research and Development Command, Fort Detrick. Document no. AD A197799.
*Army. 1989. Evaluation of four well casing materials for monitoring selected trace level organics in ground water. Aberdeen Proving Ground, MD: U.S. Army Toxic and Hazardous Materials Agency. Document no. AD A2165025.
Asherson GL, Dieli F. 1992. Immune deviation in the mouse: transfer of selective depression of contact sensitivity and interleukin-2 response with retension of interferon-gamma production requires CD8+ T cells. Immunology 76:427–432.1526651
*Atkinson R. 1985. Kinetics and mechanisms of the gas-phase reactions of the hydroxylradical with organic compounds under atmospheric conditions. Chem Rev 85:69–201.
*Atkinson R. 1987. A structure-activity relationship for the estimation of rate constants for the gas-phase reactions of OH radicals with organic compounds. International Journal of Chemical Kinetics 19:799–828.
Atkinson R, Tuazon EC, Wallington TJ, 1987. Atmospheric chemistry of aniline, N,N-dimethylaniline, pyridine, 1,3,5-triazine, and nitrobenzene. Environ Sci Technol 21:64–72.
*ATSDR. 1987. Health assessment for Alabama Army Ammunition Plant, Talladega County, Alabama, region 4. Atlanta, GA: Agency for Toxic Substances and Disease Registry. CERCLIS no. AL6210020008.
*ATSDR. 1989a. Health assessment for Comhusker Army Ammunition Plant, Grand Island, Nebraska, region 7. Atlanta, GA: Agency.for Toxic Substances and Disease Registry. CERCLIS no. NE2213820234.
*ATSDR. 1989b. Health assessment for Louisiana Army Ammunition Plant, Shreveport, Webster County, Louisiana, region 6. Atlanta, GA: Agency for Toxic Substances and Disease Registry. CERCLIS no. LA0213820533.
*ATSDR. 1989c. Health assessment for Milan Army Ammunition Plant, Milan, Carol, and Gibson Counties, Tennessee, region 4. Atlanta, GA: Agency for Toxic Substances and Disease Registry. CERLIS no. TND210020582.
*ATSDR. 1989d. Health assessment for Savanna Army Depot, Savanna, Carroll County, Illinois, region 5. Atlanta, GA: Agency for Toxic Substances and Disease Registry. CERCLIS no. ILO213820376.
*ATSDR. 1989e. Decision guide for identifying substance-specific data needs related to toxicological profiles. Agency for Toxic Substances and Disease Registry, Division of Toxicology, Atlanta, GA.
*ATSDR/CDC. 1990. Subcommittee report on biological indicators of organ damage. Agency for Toxic Substances and Disease Registry, Centers for Disease Control and Prevention, Atlanta, GA.
*Austern BM, Dobbs RA, Cohen JM. 1975. Gas-chromatographic determination of selected organic compounds added to wastewater. Environ Sci Technol 9:588–590.
*Bailey E, Peal JA, Philbert M. 1988. Determination of 1,3-dinitrobenzene and its metabolites in rat blood by capillary gas chromatography with electron-capture detection. Journal Chromatography Biomedical Applications 425: 187–192.
*Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
*Bauer CF, Koza SM, Jenkins TF, 1990. Liquid chromatographic method for determination of explosives residues in soil: Collaborative study. J Assoc Off Anal Chem 73:541–552.
Benziger TM. 1977. Method for the production of high-purity triaminotrinitrobenzene (Patent). Washington, DC: Energy Research and Development Administration.
Bhatia K. 1975. Hydroxyl radical induced oxidation of nitrobenzene. J Phys Chem 79:1032–1038.
*Bidleman TF. 1988. Atmospheric processes. Wet and dry deposition of organic compounds are controlled by their vapor-particle partitioning. Environ Sci Technol 22: 361–367
*Blackbum DM, Gray AJ, Lloyd SC, 1988. A comparison of the effects of the three isomers of dinitrobenzene on the testis in the rat. Toxicol Appl Pharmacol 92:54–64.3341027
Bronaugh RL, Maibach HI. 1985. Percutaneous absorption of nitroaromatic compounds: In vivo and in vitro studies in the human and monkey. J Invest Dermatol 84:180–183.3919108
Brown CD, Miller MG. 1989.. Relationship between testicular cell culture age and susceptibility to 1,3-dinitrobenzene induced toxicity [Abstract]. 28th Annual Meeting, Society of Toxicology, Atlanta, Ga.
Capellos C, Suryanarayanan K. 1973. Flash photolysis of s-trinitrobenzene solutions. Int J Chem Kinetics 5:305–320.
*Cave DA, Foster PMD. 1990. Modulation of m-dinitrobenzene and m-nitrosonitrobenzene toxicity in rat sertoli-germ cell cocultures. Fundam Appl Toxicol 14: 199–207.2307317
*CELDS. 1991. Computer-Environmental Legislative Data Systems. University of Illinois, Urbana, IL. June 20, 1991.
*CELDS. 1993. Computer-aided Environmental Legislative Database. University of Illinois at Urbana.
*Chambers CW, Tabak HH, Kabler PW. 1963. Degradation of aromatic compounds by phenol-adapted bacteria. J Water Pollut Contr Fed 35:1517–1528.
*Chiu CW, Lee LH, Wang CY, 1978. Mutagenicity of some commercially available nitro compounds for Salmonella typhimurium. Mutat Res 58:11–22.362191
*CLPSD. 1989. Contract Laboratories Program Statistical Database. U.S. Environmental Protection Agency, Washington, DC. July, 1989.
*Cody TE, Witherup S, Hastings L. 1981. 1,3-Dinitrobenzene: Toxic effects in vivo and in vitro. J Toxicol Environ Health 7:829–848.7265311
*Cooper SW, Jayanty RKM, Knoll JE, 1986. Determination of selected nitrogen-containing hazardous pollutants in complex matrices by gas chromatography with a nitrogen-phosphorus. J Chromatogr Sci 24:204–209.
*Cossum PA, Rickert DE. 1985. Metabolism of dinitrobenzenes by rat isolated hepatocytes. Drug Metab Dispos 13:664–668.2867868
*Cossum PA, Rickert DE. 1987. Metabolism and toxicity of dinitrobenzene isomers in erythrocytes from Fischer-344 rats, rhesus monkeys and humans. Toxicol Lett 37:157–163.3603589
Cowen WF, Baynes RK. 1980. Estimated application of gas chromatographic headspace analysis to priority pollutants. J Environ Sci Health 15:413–427.
*Dangwal SK. 1981. A quantitative paper chromatographic method of separation of nitrobenzene and p-nitrobenzene in air samples. American Industrial Hygiene Association Journal 42:557
*Dangwal SK, Jethani BM. 1980. Simple method of determination of nitrobenzene and chloronitrobenzene in air and urine. American Industrial Hygiene Association Journal 41:847–850.7457378
Davis EM, Murray HE, Liehr JG, 1981. Basic microbial degradation rates and chemical by-products of selected organic compounds. Water Research 15:1125-l 127.
Deichmann WB, Gerard HW. 1969. Toxicology of drugs and chemicals. 4th ed. New York, NY: Academic Press, 226.
*Deneer JW, Sinnige TL, Seinen W. 1987. Quantitative structure-activity relationships for the toxicity and bioconcentration factor of nitrobenzene derivatives towards the guppy (Poecilia reticulata). Aquat Toxicol 10:115–129.
*Desai LS, Austin A, Fitzgerald GB, 1991. Acute toxicity evaluation of nitroaromatic compounds. The Toxicologist 11:145. [abstract]
Devault DS. 1985. Contaminants in fish from Great Lakes Harbors and tributary mouths. Arch Environ Contam Toxicol 14:587–594.
*Dey S, Godbole SH. 1986. Biotransformation of m-dinitrobenzene by Candida-pulcherrima. Indian J Exp Biol 24:29–33.
*Dey S Kanekar P, Godbole SH. 1986. Aerobic microbial degradation of m-dinitrobenzene. Indian J Environ Health 29:118–128.
*Dickel 0, Knackmuss HJ. 1991. Catabolism of the 1,3-dinitrobenzene by Rhodococcus sp. QT-1. Arch Microbial 157: 76–79
*Donovan JW. 1990. Nitrates, nitrites, and other sources of methemoglobinemia. In: Haddad LM and Winchester JF, eds. Clinical management of poisoning and drug overdose. 2nd ed. Philadelphia, PA: W.B. Saunders Company, p.1419–1431.
*DOT. 1989a. Department of Transportation. Code of Federal Regulations 49 CFR 172.101.
*DOT. 1989b. Department of Transportation. Federal Register 54 (185):39501–39505.
*Douse JMF. 1985. Trace analysis of explosives at the low nanogram level in handswab extracts using columns of Amberlite XAD-7 porous polymer beads and silica capillary column gas chromatography with thermal energy analysis and electron-capture detection. J Chromatogr 328:155–165.
*Eisenreich SJ, Looney BB, Thornton JD. 1981. Airborne organic contaminants in the Great Lakes Ecosystem. Environ Sci Technol 15:30–38
*Ellenhorn MJ, Barceloux DG. 1988. Nitrates, nitrites, and methemoglobinemia. In: Medical toxicology: Diagnosis and treatment of human poisoning. New York, NY: Elsevier, 844–851.
*Ellis MK, Foster PMD. 1992. The metabolism of 1,3-dinitrobenzene by rat testicular subcellular fractions. Toxicology Letters 62:201–208.1412504
*Ellis MK, Hill S, Foster PMD. 1992. Reactions of nitrosonitrobenzenes with biological thiols: identification and reactivity of glutathion-S-y1 conjugates. Chem-Biol Interactions 82: 151–163
*EPA. 1976. Investigation of selected potential environmental contaminants. Washington, DC: U.S. Environmental Protection Agency.
*EPA. 1978. Designation of hazardous substances. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 116.4.
*EPA. 1980a. Discarded commercial chemical products, off-specification species, container residues, and spill residues thereof. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 261.33.
*EPA. 1980b. Hazardous waste management system: Identification and listing of hazardous waste. U.S. Environmental Protection Agency. Federal Register 45(229):78530–78550.
*EPA. 1981. Engineering handbook for hazardous waste incineration. Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development.
*EPA. 1982a. Chemical Information Rules. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 712.
*EPA. 1982b. Health and safety data reporting. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 716.
*EPA. 1985a. Designation of hazardous substances. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 302.4.
*EPA. 1985b. Designation, reportable quantities, and notification. U.S. Environmental Protection Agency. Federal Register 50(65):13474-l 3522.
EPA. 1985c. Health and environmental effects profile on dinitrobenzenes (o-, m-, p-). Office of Solid Waste and Emergency Response. Washington, DC: U.S. Environmental Protection Agency, NTIS PB 88-173638.
EPA. 1985d. Nitrobenzene. In: EPA chemical profiles. Washington, DC: U.S. Environmental Protection Agency.
*EPA. 1986a. Test methods for evaluating solid waste. 3rd ed. SW-846. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
*EPA. 1986b. Treatment standards expressed as specified technologies. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268.42.
*EPA. 1986c. Toxic Chemical Release Reporting. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.
*EPA. 1987a. Ground wirer monitoring list. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 264, Appendix IX.
*EPA. 1987b. Hazardous materials table and hazardous materials communications regulations. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 116.4.
EPA. 1987c. Hazardous materials table and hazardous materials communications regulations. U.S. Environmental Protection Agency. Federal Register 52(31):4825–4843.
EPA. 1987d. List (phase I) of hazardous constituents for ground-water monitoring. U.S. Environmental Protection Agency. Federal Register 52( 131):25942–25952.
*EPA. 1988a. Hazardous constituents. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261, Appendix VIII.
*EPA. 1988b. Hazardous waste management system: Identification and listing of hazardous waste. U.S. Environmental Protection Agency. Federal Register 53(78):13382–13393.
*EPA. 1988c. Toxic Chemical Release Reporting. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.
*EPA. 1988d. Health and Safety Data Reporting. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 716.
EPA. 1989. Toxicological profile for 1,3,Qinitrobenzene. Washington, DC: U.S. Environmental Protection Agency, Criteria and Standards Division, Office of Drinking Water.
*EPA. 1990a. Discarded commercial chemical products, off-specification species, container residues and spill residues thereof. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.33.
*EPA. 1990b. Interim methods for development of inhalation reference doses. U.S. Environmental Protection Agency. EPA/600/8-90/066A.
*EPA. 1991a. Municipal Solid Waste: Appendix II - List of Hazardous Inorganic and Organic Constituents. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 258.
*EPA. 1991b. Health advisory for 1,3-dinitrobenzene. U.S. Environmental Protection Agency, Washington, DC: Criteria and Standard Division. PB 91-159640
*EPA. 1994. Drinking Water Regulations and Health Advisories. U.S. Environmental Protection Agency. May 1994.
Evans VH. 1977. Optimization of TATB processing. Mason and Hanger-Silas Mason Co., Inc., Amarillo, TX.
*Evenson DP, Janca FC, Baer RK, 1989a. Effect of 1,3-dinitrobenzene on prepubertal, pubertal, and adult mouse spermatogenesis. J Toxicol Environ Health 28:67–80.2778849
*Evenson DP, Janca FC, Jost LK, 1989b. Flow cytometric analysis of effects of 1,3,-dinitrobenzene on rat spermatogenesis. J Toxicol Environ Health 28:81–98.2778850
Facchini V, Griffiths LA. 1981. The involvement of the gastro-intestinal microflora in nitro-compound-induced methaemoglobinaemia in rats and its relationship to nitrogoup reduction. Biochem Pharmacol 30:931–935.7236314
*FEDRIP. 1994. Federal Research in Progress. Dialog Information Service, Inc., June 1991.
*Feltes J, Levsen K. 1989. Reversed phase high-performance liquid chromatographic determination with photodiode-array detection of nitroaromatics from former ammunition plants in surface waters. J High Resolut Chromatogr 12:613–619.
*Feltes J, Levsen K, Volmer D, 1990. Gas chr,omatographic and mass spectrometric determination of nitroaromatics in water. J Chromatogr 518:21–40.2258406
Fletcher JS, McFarlane JC, Pfleeger T, 1990. Influence of root exposure concentration on the fate of nitrobenzene soybean. Chemosphere 20:513–523.
Fogleman RW, Elsea JR, Paynter OE, 1955. Health and environmental effects profile for trinitrobenzene. Agric Food Chem 3:936.
*Foster PM. 1989. M-dinitrobenzene: Studies on its toxicity to the testicular sertoli cell. Arch Toxicol Suppl 13:3–17.2774949
*FSTRAC. 1990. Summary of State and Federal Drinking Water Standards and Guidelines. U.S. Environmental Protection Agency, Federal-State Toxicology and Regulatory Alliance Committee.
Furukawa H, Kawai K. 1985. Mutagenicity-structure relationship of dinitrobenzene derivatives [Abstract]. Mutat Res 147:256.
*Furukawa H, Kawai N, Kawai K. 1985. Frameshift mutagenicity of dinitrobenzene derivatives on Salmonella typhimurium TA98 and Tm elevation of calf thymus DAN by dinitrobenzene derivatives. Nucleic Acids Symp Ser, 5–8.3911171
Garman JR, Freund T, Lawless EW. 1987. Testing for groundwater contamination at hazardous waste sites. J Chromatogr Sci 25:328–337.
*Gamer R, Nutman CA. 1977. Testing of some azo dyes and their reduction products for mutagenicity using Salmonella typhimurium TA1538. Mutat Res 44:9–19.331098
Giorgini S, Spallanzani P, Fabbri P, 1978. A case of multiple sensitization to three halogeno-substituted mono-nitrobenzenes. Ital Gen Rev Dermatol 15:107–112.553074
Gitchell A, Simonaitis R, Heicklen J. 1974. The inhibition of photochemical smog: II. Inhibition by hexafluorobenzene, nitrobenzene, naphthalene, and 2,6-tert-butyl-4-methylphenol. J Air Pollut Control Assoc 24:772–775.
*Goldfrank LR, Flomenbaum NE, Lewin, , eds. 1990. Goldfrank’s toxicologic emergencies. 4th ed. Norwalk, CT: Appleton & Lange, p.210, 394-395, 396, 398.
Goldstein RS, Rickert DE. 1984. Relationship between red blood cell uptake and methemoglobin production by nitrobenzene and dinitrobenzene in vitro. Life Sci [I] 36:121–126.
Gomolka E, Gomolka B. 1979. Ability of activated sludge to degrade nitrobenzene in municipal wastewater. Acta Hydrochim Hydrobiol 79:605–622.
Gorski T. 1969. Biological role of charge-transfer complexes of aromatic hydrocarbon oxy derivatives in chemical carcinogenesis. Neoplasma 16:403–408.4310102
Grant WM. 1986. Toxicology of the eye. 3rd ed. Springfield, IL: Charles C. Thomas, Publisher, 953.
*Grab RL, Cao KB. 1990. High-performance liquid chromatographic study of the recovery of aromatic amine and nitro compounds from soil. J Environ Sci Health Part A Environ Sci Eng 25:117–136.
Grosjean D. 1990. Atmospheric chemistry of toxic contaminants: 1. Reaction rates and atmospheric persistence. J Air Waste Manage Assoc 40:1397–1402.
Guittonneau S, De Laat J, Dore M, 1988. Comparative study of the photodegradation of aromatic compounds in water by UV and hydrogen peroxide-UV. Environ Technol Lett 9: 1115–1128.
*Haderlein SB, Schwarzenbach RP. 1993. Adsorption of substituted nitrobenzenes and nitrophenols to mineral surfaces. Environ Sci Technol 27:316–326
*Hallas LE, Alexander M. 1983. Microbial transformation of nitroaromatic compounds in sewage effluent. Appl Environ Microbial 45:1234–1241.
*HAZDAT. 1994. Database. Agency for Toxic Substances and Disease Registry (ATSDR), Atlanta, GA.
*Hennion MC, Coquart V. 1993. Comparison of reverse-phase extraction sorbents for the on-line trace enrichment of polar organic compounds in environmental aqueous samples. J Chromatogr 642: 211–224.
*Hess RA, Linder RE, Strader LF, 1988. Acute effects and long-term sequelae of 1,3-dinitrobenzene on male reproduction in the rat: II. Quantitative and qualitative histopathology of the testis. J Androl 9:327–342.3235380
*Higson FK. 1992. Microbial degradation of nitroaromatic compounds. Adv Appl Microbial 37: 1–19.
*Hine J, Mookerjee PK. 1975. The intrinsic hydrophilic character of organic compounds: Correlations in terms of structural contributions. J Org Chem 40:292–298.
Holloway AJ, Moore HD, Foster PM. 1990. The use of in vitro fertility of female rats exposed to 1,3-dinitrobenzene. Fundam Appl Toxicol 14:113–122.2307310
*HSDB. 1994. Hazardous Substances Data Bank. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
Hukovi CS, Stankovi CD, Brankov K. 1969. Effect of trinitrotoluene (TNT) and nitrobenzene on the effect of stimulation of cholinergic nerves of the bladder. Arh Hig Rada Toksikol 20:267–273.5200802
Hunter D. 1978. The diseases of occupations. 6th ed. London, England: Hodder and Stoughton, 518–522.
Ince N, Inel Y. 1989. Volatilization of organic, chemicals from water. Water Air Soil Pollut 47:71–80.
*IRIS. 1994. Integrated Risk Information Systems. U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Environmental Criteria and Assessment Office, Cincinnati, OH.
*Ishihara N, Ikeda M. 1979. Effects of solvents and solutes on the percutaneous absorption of m-dinitrobenzene. Int Arch Occup Environ Health 44:91–98.521169
*Ishihara N, Kanaya A, Ikeda M. 1976. m-Dinitrobenzene intoxication due to skin absorption. Int Arch Occup Environ Health 36:161–168.1248881
*Jenkins TF, Grant CL. 1987. Comparison of extraction techniques for munitions residues in soil Anal Chem 59:1326–1331.
*Jenkins TF, Walsh ME, Schumacher PW, 1989. Liquid chromatographic method for determination .of extractable nitroaromatic and nitramine residues in soil. J Assoc Off Anal Chem 72:890–899.
*Kaden DA, Hites RA, Thilly WG. 1979. Mutagenicity of soot and associated polycyclic aromatic hydrocarbons to Salmonella typhimurium. Cancer Res 39:4152–4159.383281
Kawai A, Goto S, Matsumoto Y, 1987. Mutagenicity of aliphatic and aromatic nitro compounds - industrial materials and related compounds. Japanese Journal of Industrial Health 29:34–54.3613249
*Kebbekus BB, Bozzelli JW. 1982. Determination of selected organic vapors in air by adsorbent trapping and capillary gas chromatography. J Environ Sci Health Part A Environ Sci Eng 17:713–724.
Kenaga EE. 1980. Predicted bioconcentration factors and soil sorption coefficients of pesticides and other chemicals. Ecotox Env Safety 4:26–38.
*Kerklaan PRM, Bouter S, Koppele JM, 1987. Mutagenicity of halogenated and other substituted dinitrobenzenes in Salmonella typhimurium TAlOO and derivatives deficient in glutathione (TAlOO/GSH-) and nitroreductase (TAl OONR). Mutat Res 176: 171–178.3543663
*Kiese M. 1974. Methemoglobinemia: a comprehensive treatise. Cleveland, OH: CRC Press, 118–123.
Korolev AA, Voitesekhovskya MV, Bogdanov MV, 1977. [Experimental data for hygienic standardization of dinitrotoluene and trinitrobenzene in surface waters.] Gig Sanit 10:17. (Russian)
*Kumar A, Chawla R, Ahuja S, 1990. Nitrobenzene poisoning and spurious pulse oximetry. Anaesthesia 45:949–95 1.2252189
Letavet AA, Sanotsky IV, eds. 1973. The toxicology of new industrial chemical substances. Moscow, USSR: USSR Academy of Medical Sciences.
Leung MG, Chou IN. 1989. Relationship between l-chloro-2,4-dinitrobenzene-induced cytoskeletal perturbations and cellular glutathione. Cell Biol Toxicol 5:51–66.2645973
*Linder RE, Hess RA, Perreault SD, 1988. Acute effects and long-term sequelae of 1,3-dinitrobenzene on male reproduction in the rat. I. Sperm quality, quantity, and fertilizing ability. J Androl 9:317–326.3235379
*Linder RE, Hess RA, Strader LF. 1986. Testicular toxicity and infertility in male rats treated with 1,3-dinitrobenzene. J Toxicol Environ Health 19:477–489.3783767
*Linder RE, Strader LF, Barbee RR, 1990. Reproductive toxicity of a single dose of 1,3-dinitrobenzene in two ages of young adult male rats. Fundam Appl Toxicol 14:284–298.2318353
Liu DHW, Bailet HC, Pearson JG. 1983. Toxicity of a complex munitions wastewater to aquatic organisms. In: Bishop WE, Caldwell RD, Heidolph BB, eds. Aquatic toxicology and hazard assessment: Sixth symposium. Philadelphia, PA: American Society for Testing and Materials, 135150.
*Lloyd JBF. 1983. High-performance liquid chromatography of organic explosives components with electrochemical detection at a pendant mercury drop electrode. J Chromatogr 257:227–236.
*Lloyd JBF. 1991. Forensic explosives and firearm traces. Traping of HPLC peaks for gas chromatography. J Energetic Materials 9:1–17
*Lloyd SC, Foster PMD. 1987. 1,3-Dinitrobenzene: Toxicity and metabolism in rat testicular cell cultures. Arch Toxicol, Suppl 11:281–284.
*Lorenzo E, Alda E, Hemandez P, 1988. Voltammetric determination of nitrobenzene with a chemically modified carbon-paste electrode: Application to wines, beers, and cider. Fresenius’ Z Anal Chem 330: 139–142.
Lu P, Metcalf RL. 1975. Environmental fate and biodegradability of benzene derivatives as studied in a model aquatic ecosystem. Environ Health Perspect 10:269–284.1157796
*Lyman WJ, Reehl WF, Rosenblatt DH. 1982. Handbook of chemical property estimation methods: Environmental behavior of organic compounds. New York, NY: McGraw Hill Book Co., 4-9, 7-4, 15-16.
*Mark HF, Othmer DF, Overberger CG, , eds. 1978. Kirk-Othmer encyclopedia of chemical technology. 3rd ed. New York, NY: John Wiley and Sons, 3:749.
*Mason RP, Holtzman JL. 1975. The mechanism of microsomal and mitochondrial nitroreductase. Electron spin resonance evidence for nitroaromatic free radical intermediates. Biochemistry 14: 1626.164892
McCormick NG, Feeherry FE, Levinson HS. 1976. Microbial transformation of 2,4,6-trinitrotoluene and other nitroaromatic compounds. Appl Environ Microbial 31:949–958.
*McEuen SF, Miller MG. 1991. Metabolism and pharmacokinetics of 1,3-dinitrobenzene in the rat and the hamster. Drug Metabolism and Disposition 19:661–666.1680634
*McFarlane C, Nolt C, Wickliff C, 1987a. The uptake distribution and metabolism of four organic chemicals by soybean plants and barley roots. Environ Toxicol Chem 6:847–856.
McFarlane C, Pfleeger T, Fletcher J. 1990. Effect, uptake, and disposition of nitrobenzene in several terrestrial plants. Environ Toxicol Chem 9:513–520.
McFarlane C, Wickliff C. 1985. Excised barley root uptake of several carbon-16labeled organic compounds. Environ Monit Assess 5:385–392.24258104
McFarlane JC, Pfleeger T, Fletcher J. 1987b. Transpiration effect on the uptake and distribution of bromacil, nitrobenzene, and phenol in soybean plants. J Environ Qua1 16:372–376.
McGregor D, Prentice RD, McConville M, 1984. Reduced mutant yield at high doses in the Salmonella activation assay: The cause is not always toxicity. Environ Mutagen 6:545–558.6381041
*McGregor DB, Riach CG, Haste11 RM, 1980. Genotoxicity activity in microorganisms of tetryl, 1,3-dinitrobenzene and 1,3,5-trinitrobenzene. Environ Mutagen 2:531–541.7030731
*McLuckey SA, Glish GL, Carter JA. 1985. The analysis of explosives by tandem mass spectrometry. J Forensic Sci 30:773–788.
McMahon RE, Cline JC, Thompson CZ. 1979. Assay of 855 test chemicals in ten tester strains using a new modification of the Ames test for bacterial mutagens. Cancer Res 39:682–693.371791
*Melnikow J, Keeffe JR, Bernstein. 1981. Carcinogens and mutagens in the undergraduate laboratory. J Chem Educ 58:All-A14.
*Merck Index. 1989. The Merck index: An encyclopedia of chemicals, drugs, and biologicals. Budavari S, ed. Rahway, NJ: Merck & Co., Inc., 516, 1530.
*Mill T, Mabey W. 1985. Photochemical transformations. In: Neely WB, Blau GE, eds. Environmental exposure to chemicals. Boca Raton, FL: CRC Press, 175–216.
*Miller MG, McEuen SF, Nasiri M 1991. Application of ELISA techniques to metabolic disposition studies for 1,3-dinitrobenzenes: Comparisons with HPLC and radiochemical methods. Chem Res Toxicol 4: 324–329 1912316
MIS. 1991. ATSDR Management Information System. Agency for Toxic Substances and Disease Registry, Atlanta, GA. July 30, 1991.
*Mitchell WR, Dennis WH Jr. 1982. Biodegradation of 1,3-dinitrobenzene. J Environ Sci Health Part A Environ Sci Eng 17:837–854.
MMWR. 1988. Methemoglobinemia due to occupational exposure to dinitrobenzene: Ohio 1986. Atlanta, GA: Centers for Disease Control Morbidity and Mortality Weekly Report 37:353–355.
*Moore NP, Creasy DM, Gray TJB, 1992. Urinary creatine profiles after administration of cell-specific testicular toxicants to the rat. Arch Toxicol 66:435–442.1332651
*Murray JS, Brinck T, Politzer P. 1993. Partition coefficients of nitroaromatics expressed in terms of their molecular surface areas and electrostatic potentials. J Phys Chem 97: 13807–13809
*NAS/NRC. 1989. Biologic markers in reproductive toxicology. National Academy of Sciences/National Research Council. Washington, DC: National Academy Press, 15–35.
NATICH. 1990. National Air Toxics Information Clearinghouse. Data base report on state, local, and EPA air toxics activities. U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards, Washington, DC. September 17, 1990.
*NATICH. 1992. NATICH (National Air Toxics Information Clearinghouse) database report of federal, state, and local air toxics activities. Office of Air Quality Planning and Standards, Research Triangle Park, NC. EPA-453\R-92-008.
Navy. 1983. Synthesis and properties of trisubstituted trinitrobenzenes: TATB analogs. Silver Spring, MD: Naval Surface Weapons Center. Document no. AD A131619.
NIOSH. 1989. Dinitrobenzene. National Institute of Occupational Safety and Health Toxicology Update. J Appl Toxicol 9(3):199–202.2663961
NIOSH. 1990. NIOSH pocket guide to chemicals hazards. Washington, DC: U.S. Department of Health and Human Service, Center for Disease Control, National Institute for Occupational Safety and Health, Division of Standard Development and Technology Transfer. NIOSH publication no. 90117.
*NIOSH. 1992. Recommendations for Occupational Safety and Health: Compendium of policy documents and statements. U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health, Cincinnati, OH.
*NOES. 1991. National Occupational Exposure Survey. Cincinnati, OH: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health, Division of Surveillance, Hazard Evaluations and Field Studies.
*NREPC. 1986. Natural Resources and Environmental Protection Cabinet. Frankfort, KY: Department for Environmental Protection. 401 KAR 63:022.
NREPC. 1988. Natural Resources and Environmental Protection Cabinet. Frankfort, KY: Department for Environmental Protection. 401 KAR 31:040.
*Nystrom DD, Rickert DE. 1987. Metabolism and excretion of dinitrobenzenes by male Fischer-344 rats. Drug Metab Dispos 15:821–825.2893708
Nystrom DD, Working PK, Rickert DE. 1989. Testicular metabolism and toxicity of dinitrobenzenes [Abstract]. Society of Toxicology, CIIT, Research Triangle Park, NC.
*Obasaju MG, Katz DF, Miller MG. 1991. Species differences in susceptibility to 1,3-dinitrobenzene-induced testicular toxicity and methemoglobinemia. Fundam Appl Toxicol 16:257–266.2055357
*OHM/TADS. 1991. Oil and Hazardous Materialsmechnical Assistance Data System. Baltimore, MD: Chemical Information Systems, Inc. May, 28, 1991.
*Okubo T, Shigeta S. 1982. Anemia cases after acute m-dinitrobenzene intoxication due to an occupational exposure. Industrial Health 20:297–304.7153063
*OSHA. 1987. U.S. Department of Labor, Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.20.
*OSHA. 1988. U.S. Department of Labor, Occupational Safety and Health Administration. Federal Register 53:30163–30164.
OSHA. 1989a. Toxic and hazardous substances: Air contamin ants. U.S. Department of Labor, Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000.
*OSHA 1989b. U.S. Department of Labor, Occupational Safety and Health Administration. Federal Register 54:2920–2960.
*OTA. 1990. Neurotoxicity: Identifying and controlling poisons of the nervous system. Office of Technology Assessment, Washington, DC. OTA-BA-438.
Pankow D, Glatzel W, Tietze K, 1975. Motor nerve conduction velocity after carbon monoxide or m-dinitrobenzene poisoning following elimination of the poisons. Arch Toxicol 18:325–330.
Pankow D, Ponsold W. 1978. Urinary catecholamine excretion and blood sugar response during acute poisonings with dinitrobenzenes. Toxicology 11:377–383.749274
*Parke DV. 1961. The metabolism of m-dinitrobenzene in the rabbit. Biochem J 78:262–271.16748875
Parke DV. 1968. The biochemistry of foreign compounds. Oxford, England: Pergamon Press, 224.
Patil SA, Shinde VM. 1989. Gas chromatographic studies on the biodegradation of nitrobenzene and 2,4-dinitrophenol in the nitrobenzene plant wastewater. Environ Pollut 57:235–250.15092452
Philbert MA, Cremer JE, Nolan C, 1987a. CNS lesions induced by 1,3-dinitrbbenzene in the rat [Abstract]. Neuropathol Appl Neurobiol 13:236–237.
*Philbert MA, Gray AJ, Connors TA. 1987b. Preliminary investigations into the involvement of the intestinal microflora in CNS toxicity induced by 1,3-dinitrobenzene in male F-344 rats. Toxicol Lett 38:307–314.3660433
Philbert MA, Nolan CC, Brown AW. 1989. Acute and subacute neurotoxicity of 1,3-dinitrobenzene in male Fischer-344 rats [Abstract]. Society of Toxicology, 28th Annual Meeting, Atlanta, GA
Philbert MA, Nolan CC, Cremer JE, 1987B. 1,3-Dinitrobenzene-induced encephalopathy in rats. Neuropathol Appl Neurobiol 13:371–389.3683748
*Pospisil PA, Marcus MF, Kobus MA. 1991. The application of supercritical fluid capillary chromatography to the analysis of Appendix-VIII and IX compounds. Waste Testing and Quality Assurance: Third Volume, ASTM STP 1075, D. Friedman, Ed., American Society for Testing and Materials, Philadelphia. 154–169
*Preslan JE, Hatrel BB, Emerson E, 1993. An improved method for analysis of 2,4,6-trinitrotoluene and its metabolites from compost ‘and contaminated soils. J Hazardous Materials 33:329–337.
*Prival MJ. 1983. The Salmonella mutagenicity assay: Promises and problems. Ann NY Acad Sci 407:154–163.6349472
Probst GS, Hill LE. 1980. Chemically-induced DNA repair synthesis in primary rat hepatocytes: A correlation with bacterial mutagenicity [Abstract]. Ann NY Acad Sci 349:405–406.6939370
*Probst GS, McMahon RE, Hill CZ, 1981. Chemically-induced unscheduled DNA synthesis in primary rat hepatocyte cultures: A comparison with bacterial mutagenicity using 218 compounds. Environ Mutagen 3:11–32.7021142
Purchase IFH, Longstaff E, Ashby J, 1976. Evaluation of six short term tests for detecting organic chemical carcinogens and recommendations for their use. Nature (London) 264:624–627.794741
Ray DE, Brown AW, Cavanagh JB, 1992. Functional/metabolic modulation of the brain stem lesions caused by 1,3-dinitrobenzene in the rat. NeuroToxicology 13:379–388.1436756
*Reader SC, Shingles C, Stonard MD. 1991. Acute testicular toxicity of 1,3-dinitrobenzene arid ethylene glycol monomethyl ether in the rat: Evaluation of biochemical effect markers and hormonal responses. Fundam Appl Toxicol 16:61–70.1902188
*Reddy TV, Wan L, Lin ELC, 1991. Formation .and persistence of 1,3,5-trinitrobenzene adducts with blood proteins and tissue DNA. The Toxicologist 11:131. [abstract]
*Reddy TV, Weichman BE, Lin EL, 1993. Separation and quantitation of nitrobenzenes and their reduction products nitroanilines and phenylenediamines by reversed-phase high-performance liquid chromatography. J Chromatogr A 655:331–335.
*Rehnberg GL, Linder RE, Goldman JM, 1988. Changes in testicular and ‘serum hormone concentrations in the male rat following treatment with m-dinitrobenzene. Toxicol Appl Pharmacol 15:255–264.
*Richard JJ, Junk GA. 1986. Determination of munitions in water using macroreticular resins. Anal Chem 58:723–725.
Rickert DE. 1987. Metabolism of nitroaromatic compounds. Drug Metabolism Reviews 18:23–53.3311683
Rickert DE, Bond JA, Long RM, 1983. Metabolism and excretion of nitrobenzene by rats and mice. Toxico1 Appl Pharmacol 67:206–214.
Romero I, Brown AW, Cavanagh JB, 1991. Vascular factors in the neurotoxic damage caused by 1,3-dinitrobenzene in the rat. Neuropathology and Applied Neurobiology 17:495–508.1800913
*Roth M, Murphy JM Jr. 1978. Correlation of oxygen demand and total organic carbon test on wastewaters from ammunition plants. Proc Ind Waste Conf 32:674–688.
Saltzman S, Yariv S. 1975. Infrared study of the sorption of phenol and p-nitrophenol by montmorillonite. Soil Sci Society of America Proceedings 39:474–479.
Sanders PF, Wolfe NL. 1985. Reduction of nitroaromatic compounds in anaerobic sediment/water systems. Amer Chem Sot 25:225–226.
*Sax NI, Lewis RJ, eds. 1987. Hawley’s condensed chemical dictionary. New York, NY: Van Nostrand Reinhold Company, 420, 1190.
Shimizu M, Yano E. 1986. Mutagenicity of mono-nitrobenzene derivatives in the Ames test and ret assay. Mutat Res 170:11–22.3083245
*Shimizu M, Yasui Y, Matsumoto N. 1983. Structural specificity of aromatic compounds with special reference to mutagenic activity in Salmonella typhimurium: A series of chloro- or fluoro-nitrobenzene derivatives. Mutat Res 116:217–238.6339893
*Simmons MS, Zepp RG. 1986. Influence of humic substances on photolysis of nitroaromatic compounds in aqueous systems. Water Res 20:899–904.
*Spalding RF, Fulton JW. 1988. Groundwater munition residues and nitrate near Grand Island, Nebraska, U.S.A. Journal of Contaminant Hydrology 2:139–153.
*Spanggord RJ, Gibson BW, Keck RG, 1982a. Effluent analysis of wastewater generated in the manufacture of 2,4,6-trinitrotoluene: Characterization study. Environmental Science and Technology 16:229–232.
*Spanggord RJ, Mortelmans KE, Griffin AF, 1982b. Mutagenicity in Salmonella typhimurium and structure-activity relationships of wastewater components emanating from the manufacture of trinitrotoluene. Environ Mutagen 4: 163– 179.7042329
Spanggord RJ, Myer CJ, LeValley SE, 1990. Structure-activity relationship for the intrinsic hepatotoxicity of dinitrotoluenes. Chem Res Toxicol 3:551–558.2103326
*Stemmler EA, Hites RA. 1987. The electron capture negative ion mass spectra of 2,6-dinitroaniline and 2,4-dinitrophenol herbicides and related nitrobenzene derivatives. Biomed Environ Mass Spectrom 14:417–434.
*Swarm RL, Laskowski DA, McCall PJ, 1983. A rapid method for the estimation of the nvironmental parameters 0ctanoYwater partition coefficient, soil sorption constant, water to air,ratio, and water solubility. Residue Reviews 85:17–28
*TRI92. 1994. Toxic Chemical Release Inventory. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
*Van H, Deyrup CA,. Kavaler AR, eds. 1991. OPD chemical buyers directory 1991. 78th ed. New York, NY: Schnell Publishing Company, Inc., 12, 25, 442.
*WAC. 1988. Control of hazardous pollutants: Wisconsin Administrative Code, Chapter NR 455. Department of Natural Resources.
*P Wardman, Clarke ED. 1976. Oxygen inhibition of nitroreductase: Electron transfer from nitro radical-anions to oxygen. Biochem Biophys Res Commun 69:942.6027
*Watanabe T, Ishihara N, Ikeda M. 1976. Toxicity of and biological monitoring for 1,3-diamino-2,4,6-trinitrobenzene and other nitro-amino derivatives of benzene and chlorobenzene. Int Arch Occup Environ Health 37:157–168.977137
Wei CI, Cohen MD, Swartz DD, 1984. Mutagenicity studies of some nitroaromatics with regular Salmonella typhimurium strains and their corresponding nitroreductase-deficient strains. Environ Mutagen 6:410.
*White RP, Hay J. 1901. Some recent inquiries and researches into the poisonous properties of naphthalene and the aromatic compounds. Lancet 2:582–584.
Williams GM. 1977. Detection of chemical carcinogens by unscheduled DNA synthesis in rat liver primary cell cultures. Cancer Res 37:1845–1851.404038
Williams J, Foster PM. 1989. The effects of 1,3-dinitrobenzene and mono-(2-ethylhexyl) phthalate on hormonally stimulated,lactate and pyruvate production by rat Sertoli cell cultures. Toxicol Lett 47:249–257.2546297
Woollen BH, Guest EA, Gray AJ, 1986. 1,3-Dinitrobenzene: The use of rat and human pharmacokinetic measurements in risk assessment. Hum Toxico1 5:407.
*Yinon J, Laschever M. 1982. Direct-injection chemical ionization mass spectrometry of explosives in water. European Journal of Mass Spectrometry in Biochemical, Medicine, and Environmental Research 2:101–104.