# 7 REGULATIONS AND ADVISORIES

The international, national, and state regulations and guidelines regarding 1,3-DNB and 1,3,5-TNB in air, water, and other media are summarized in Table 7-1.

ATSDR has derived two MRL values for 1,3-DNB. An acute-duration oral MRL of 0.08 mg/kg/day was derived for 1,3-DNB based on a NOAEL for testicular damage in male rats administered a single dose of 1,3-DNB by gavage (Linder et al. 1990).

An intermediate-duration oral MRL of 0.0005 mg/kg/day was derived for 1,3-DNB based on a LOAEL for hematological effects in male rats administered 1,3-DNB by gavage intermittently for 12 weeks (Linder et al. 1986).

The EPA reference dose (RfD) is 1×10^−4^ mg/kg/day for 1,3-DNB and is based on spleen enlargement in rats (IRIS 1994). The EPA RfD for 1,3,5-TNB is 5×10^−5^ mg/kg/day and is extrapolated from the RfD for 1,3-DNB based on the structural similarity.

EPA has assigned 1,3-DNB a weight-of-evidence carcinogenic classification of D, which indicates that 1,3-DNB is not classifiable as to human carcinogenicity (IRIS 1994). EPA has not assigned a weightof-evidence carcinogenic classification for 1,3,5-TNB.

1,3-DNB and 1,3,5-TNB are designated as hazardous substances (EPA 1978, 1987b) and are subject to groundwater monitoring requirements (EPA 1987a, 1988b).

The transportation.of explosives, including 1,3-DNB and 1,3,5-TNB, must be in accordance with the Department of Transportation hazardous material regulations (49 CFR 171-190) and the motor carrier safety regulations (49 CFR 390-398). Numerous states have established regulations on explosives for air quality control, solid waste disposal, storage, manufacture, and use.

OSHA requires employers of workers who are occupationally exposed to 1,3-DNB to institute engineering controls and work practices to reduce and maintain employee exposure at or below permissible exposure limits (PEL). The employer must use engineering and work practice controls, if feasible, to reduce exposure to or below an 8-hour time-weighted average (TWA) of 1.0 mg/m^3^ (skin designation) for 1,3-DNB. No value has been designated for 1,3,5-TNB. Respirators must be provided and used during the time period necessary to install or implement feasible engineering and work practice controls. Also, special protective measures should be taken to significantly reduce or preclude skin contact.

1,3-DNB is regulated as a toxic chemical under the Emergency Planning and Community Right-tol$ now Act (EPCRA) (EPA 1986c) and the Toxic Substances Control Act (TSCA) for preliminary assessment of new products (EPA 1982a) and health and safety data reporting (EPA 1982b).

The Resource Conservation and Recovery Act (RCRA) identifies both compounds for groundwater monitoring at hazardous waste management facilities (EPA 1987a). RCRA also designates 1,3,5-TNB as a hazardous waste when it occurs as a discarded commercial product, off-spec species, container - residue, or spill residue (EPA 1980a).

Table 7-1 Regulations and Guidelines Applicable to 1,3-DNB and 1,3,5-TNB

Agency | Description | Information | Reference
[underlined: NATIONAL]
Regulations:
a. Air:
OSHA | PEL TWA (skin designation) (1,3-DNB) | 1 mg/m^3^ | OSHA 1989a (29 CFR 1910.1000)
| | | OSHA 1989b
OSHA | Meets criteria for medical records (1,3-DNB) | Yes | OSHA 1987 (29 CFR 1910.20)
| | | OSHA 1988
b. Other
EPA-OERR | Reportable quantity:
| 1,3-DNB | 100 lb. | EPA 1985a (40 CFR 302.4)
| 1,3,5-TNB | 10 lb. | EPA 1985a (40 CFR 302.4)
| | | EPA 1985b
EPA-OERR/CEPP | Chemicals and chemical categories to which this part applies (1,3-DNB) | 25.000 lbs. mfd. or processed; 10.000 lbs. otherwise used | EPA 1988c (40 CFR 372.65)
EPA-OSW | Designated as a hazardous substance (1,3-DNB, 1,3,5-TNB) | Yes | EPA 1978 (40 CFR 116.4)
| | | EPA 1987b
| Listing as a hazardous waste: Discarded commercial chemical product off-specification species, container residues, and spill residues thereof (1,3,5-TNB) | Yes | EPA 1980a (40 CFR 261.33)
| Listing as a hazardous waste: Discarded commercial chemical product off-specification species, container residues, and spill residues thereof (1,3,5-TNB) | | EPA 1980b
| Municipal Solid Waste Landfills: Appendix II | | EPA 1991a (40 CFR 258)
| 1,3-DNB | 20 μg/L | EPA 1991a (40 CFR 258)
| TNB (sym) | 10 μg/L (Practical Quantitation Limit)
| Groundwater Monitoring List: Appendix IX | | EPA 1987a (40 CFR 264)
| 1,3-DNB | 10 μg/L | EPA 1987a (40 CFR 264)
| 1,3,5-TNB | 10 μg/L (Practical Quantitation Limit)
| Hazardous Constituents: Appendix VIII (1,3,5-TNB) | none | EPA 1988a (40 CFR 261)
| Treatment Standards Expressed as Specified Technologies (1,3,5-TNB) | none | EPA 1986b (40 CFR 268.42)
EPA/OPTS | Chemical lists and reporting periods (1,3-DNB) | none | EPA 1982a (40 CFR 712.30)
| Substances and listed mixtures to which this subpart applies (1,3-DNB) | none | EPA 1988d (40 CFR 716.120)
DOT | Poison B (1,3,5-DNB/solid and solution) | Yes | DOT 1989a (49 CFR 172.101)
| | | DOT 1989b
| Class A explosive (high explosive); Domestic transportation limited to road and water (cargo only, in magazines) (1,3,5-TNB/dry) | Yes
DOT | Designated as a hazardous substance subject to requirements for packaging, labeling, and transportation (1,3-DNB, 1,3,5-TNB) | Yes | DOT 1989a (49 CFR 172.101)
| Designated as a hazardous substance subject to requirements for packaging, labeling, and transportation (1,3-DNB, 1,3,5-TNB) | | Appendix A
| | | DOT 1989b
Guidelines:
a. Air
ACGIH | TLV TWA (skin designation) (1,3-DNB) | 1.0 mg/m^3^ | ACGIH 1994
| | 0.15 ppm
NIOSH | Recommended Exposure Limit (10-hour TWA) (DNB) | 1.0 mg/m^3^ | NIOSH 1992
b. Water
EPA/OW | 10-d Health Advisory (child) | 0.04 mg/L | EPA 1994
| 1-d Health Advisory (child) | 0.04 mg/L | EPA 1994
| Lifetime Health Advisory (adult) | 0.001 mg/L | EPA 1994
EPA/ODW | Drinking Water Guideline | 2.0 μg/L | FSTRAC 1990
c. Other
EPA | 1,3-DNB: | | IRIS 1994
| RfD (oral) | 1.0×10^−4^ mg/kg/day
| Carcinogenic classification | D^a^
| Unit risk (air) | ND
| Unit risk (water) | ND
| 1,3,5-TNB: | | IRIS 1994
| Rfd (oral) | 5.0×10^−5^mg/kg/day
| Carcinogen classification | ND
| Unit risk (air) | ND
| Unit risk (water) | ND
[underlined: STATE]
Regulations and Guidelines:
a. Air:
| Acceptable Ambient Air Concentrations (1,3-DNB) | | NATICH 1992
CT | 8 hr avg. time | 20.0 μg/m^3^
FL-Tampa | 8 hr avg. time | 0.01 mg/m^3^
FL-Ft. Lauderdale | 8 hr avg. time | 0.01 mg/m^3^
MD | | 0.00
ME | | 0.00
ND | 8 hr avg. time | 0.01 mg/m^3^
NV | 8 hr avg. time | 0.024 mg/m^3^
NY | 1 yr avg. time | 3.30
SC | 24 hr avg. time | 10.0 μg/m^3^
TX | 30 min avg. time | 10.0 μg/m^3^
TX9 | 30 min. avg. time | 1.00 μg/m^3^
VA | 24 hr avg. time | 17.0 μg/m^3^
KY | Significant emission levels of toxic air pollutants (1,3-DNB) | 2.551×10^−4^ pounds/hour | NREPC 1986 (410 401 63:022)
WI | Hazardous air contaminants with acceptable ambient air concentrations (1,3-DNB) | Yes | WAC 1988
b. Other | Transportation of explosives is in accordance with the U.S. Department of Transportation hazardous materials regulations 49 CFR 171-190 and the motor carrier safety regulations 49 CFR 390-398 with some exceptions or additional requirements that vary from state to state. (1,2-DNB; 1,3,5-TNB). | | CELDs 1991
AL | | Yes
AK | | Yes
AZ | | Yes
CA | | Yes
CT | | Yes
CO | | Yes
DE | | Yes
FL | | Yes
GA | | Yes
HI | | Yes
ID | | Yes
IN | | Yes
IA | | Yes
LA | | Yes
MD | | Yes
MA | | Yes
MI | | Yes
MN | | Yes
MS | | Yes
MO | | Yes
MT | | Yes
NE | | Yes
NJ | | Yes
NM | | Yes
NC | | Yes
ND | | Yes
NY | | Yes
OH | | Yes
OR | | Yes
RI | | Yes
SD | | Yes
TN | | Yes
TX | | Yes
UT | | Yes
VA | | Yes
VT | | Yes
WA | | Yes
WA-DC | | Yes
WV | | Yes
WI | | Yes
WY | | Yes
| Rules and regulations for air quality control and/or solid waste disposal have been established for explosives in general. The regulations vary from state to state (1,3-DNB; 1,3,5-TNB). | | CELDs 1991
AL | Pretreatment standards for discharge | Yes
| Hazardous waste: Thermal treatment | Yes
AZ | Solid waste collection | Yes
AR | Solid waste storage and collection | Yes
CO | Fugitive dust | Yes
CT | Hazardous waste: Thermal treatment | Yes
FL | Hazardous waste: Thermal treatment | Yes
GA | Open burning | Yes
IL | Sewer discharge | Yes
IN | Open burning | Yes
KY | Hazardous waste management | Yes
LA | Open burning | Yes
MN | Hazardous waste management | Yes
NH | Open burning | Yes
NJ | Hazardous waste management | Yes
NM | Hazardous waste management | Yes
NV | Hazardous waste management | Yes
NC | Hazardous waste: Thermal treatment | Yes
ND | Fugitive emissions | Yes
PA | Fugitive emissions | Yes
SC | Open burning | Yes
TN | Hazardous waste: Thermal treatment | Yes
UT | Hazardous waste management | Yes
VT | Open burning | Yes
VA | Solid waste management | Yes
WI | Open burning and malodorous emissions | Yes
| Hazardous Constituent | | CELDs 1993
CO | (1,3-DNB; 1,3,5-TNB) | none
IL | (1,3-DNB; 1,3,5-TNB) | none
LA | (1,3-DNB; 1,3,5-TNB) | none
MN | (1,3-DNB; 1,3,5-TNB) | none
ND | (1,3-DNB; 1,3,5-TNB) | none
WV | (1,3-DNB; 1,3,5-TNB) | none
WI | (1,3-DNB; 1,3,5-TNB) | none
| Groundwater Monitoring | | CELDs 1993
CO | (1,3-DNB; 1,3,5-TNB) | none
IL | (1,3-DNB; 1,3,5-TNB) | none
LA | (1,3-DNB; 1,3,5-TNB) | none
MN | (1,3-DNB; 1,3,5-TNB) | none
WV | (1,3-DNB; 1,3,5-TNB) | none
WI | (1,3-DNB; 1,3,5-TNB) | none
| Explosive control laws regulate storage, manufacture, and use. The regulations vary from state to state (1,3-DNB; 1,3,5-TNB). | | CELDs 1991
AK | | Yes
CA | | Yes
CT | | Yes
GA | | Yes
HI | | Yes
IN | | Yes
IA | | Yes
KS | | Yes
NJ | | Yes
MS | | Yes
NB | | Yes
NJ | | Yes
OK | | Yes
OR | | Yes
WA-DC | | Yes
WV | | Yes
WI | | Yes
KY | Listing as a hazardous waste (1,3,5-TNB) | Yes | NREPC 1986 (401 MASS 31:040)

NOTE: Units in table reflect values and units of measure designated by each agency in its regulations or advisories.

a Not classifiable as to human carcinogenicity.

ACGIH = American Conference of Governmental and Industrial Hygienists; CELDs = Comprehensive Environmental Legislative Database; CEPP = Chemical Emergency Preparedness and Prevention; CFR = Code of Federal Regulations; D = not classifiable as to human carcinogenicity; DOT = Department of Transportation; EPA = Environmental Protection Agency; FSTRAC = Federal-State Toxicology and Regulatory Alliance Committee; IRIS = Integrated Risk Information System; ND = No data; NIOSH = National Institute for Occupational Safety and Health; ODW = Office of Drinking Water; OERR = Office of Emergency and Remedial Response; OPTS = Office of Pesticides and Toxic Substances; OSHA = Occupational Safety and Health Administration; OSW = Office of Solid Waste; OW = Office of Water; PEL = Permissible exposure limit; REL = Recommended Exposure Limits; RfD = Reference dose; TLV = Threshold limit value; TWA = Time weighted average