# 3 CHEMICAL AND PHYSICAL INFORMATION

## 3.1 CHEMICAL IDENTITY

Information regarding the chemical identity of 1,3-DNB and 1,3,5-TNB is located in Table 3-1.

## 3.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of 1,3-DNB and 1,3,5-TNB is located in Table 3-2.

TABLE 3-1 Chemical Identity of 1,3-DNB and 1,3,5-TNB

Characteristic | 1,3-DNB^a^ | 1,3,5-TNB^b^
Chemical name | 1,3-Dinitrobenzene | 1,3,5-Trinitrobenzene
Synonym(s) | m-Dinitrobenzene; 1,3-dinitrobenzol; binitrobenzol; m-DNB; dinitrobenzene | sym-trinitrobenzene; TNB; trinitrobenzene
Registered trade name(s) | No data | No data
Chemical formula | C_6_H_4_N_2_O_4_^c^ | C_6_H_3_N_3_O_6_^c^
Chemical structure | [image] ^d^ | [image] ^c^
Identification numbers:
CAS Registry | 99-65-0 | 99-35-4
NIOSH RTECS | CZ7350000 | DC3850000
EPA Hazardous Waste | No data | U234
OHM/TADS | 7800093^e^ | 8400321^e^
DOT/UN/NA/IMCO | UN1597;IMO 6.1 | UN1354; IMO 4.1; UN0214; IMO 1.1
HSDB | 4017 | 6005
NCI | No data | No data

a Unless otherwise noted, all references for 1,3-DNB are HSDB 1994

b Unless otherwise noted, all references for 1,3,5-TNB are HSDB 1994

c Merck 1989

d Spanggord et al. 1982a

e OHM/TADS 1991

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substance Data Bank from National Library of Medicine; IARC = International Agency for Research on Cancer; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances; STCC = Standard Transport Commodity Code

TABLE 3-2 Physical and Chemical Properties of 1,3-DNB and 1,3,5-TNB

Property | 1,3-DNB^a^ | 1,3,5-TNB^b^
Molecular weight | 168.11^c^ | 213.11^c^
Color | Yellow^d^ | Yellow^d^
Physical state | Solid^d^ | Solid^d^
Melting point | 90 °C^c^ | 122.5 °C^c^
Boiling point | 300–303 °C^c^ | 315 °C
Density, g/cm^3^ | 1.575 at 18 °C^c^ | 1.76 at 20 °C^e^
Odor | No data | No data
Odor threshold:
Air | No data | No data
Water | No data | No data
Solubility:
Water at 20 °C | 0.5 g/L^e^ | 3.5 g/L^e^
Organic solvent(s) | Soluble in chloroform, ethyl acetate, benzene, alcohol^e^ | Soluble in benzene, methanol, alcohol, ether and carbon disulfide^e^
Partition coefficients:
Log K_ow_ | 1.49^f^ | 1.18^f^
Log K_oc_ | 2.33^h,i^ | 1.88^g,i^
Vapor pressure
at 20 °C | < 1.0 mm Hg | No data
at 25 °C | No data | 3.2×10^−6^ mm Hg^j^
Henry’s law constant:
at 20 °C | 2.3×10^−6^ atm-m^3^/mol^k^ | No data
at 25 °C | 2.33×10^−6^ atm-m^3^/mol | 3.08×10^−9g^
Autoignition temperature | No data | No data
Flashpoint | 302 °F | No data
Flammability limits
at 25 °C | No data | No data
Conversion factors^i^ | 1 ppm = 6.86 mg/m^3^ | 1 ppm = 8.70 mg/m^3^
Explosive limits | No data | No data

a Unless otherwise noted, all references for 1,3-DNB are HSDB 1994

b Unless otherwise noted, all references for 1,3,5-TNB are HSDB 1994

c Lide 1990

d Sax and Lewis 1987

e Merck 1989

f Hennion and Coquart 1993; Murray et al. 1993

g DeNeer et al. 1987

h Army 1987b

i Calculated value

j Extrapolated value

k EPA 1985a