# APPENDIX B ACRONYMS, ABBREVIATIONS, AND SYMBOLS

ACGIH: American Conference of Governmental Industrial Hygienists
ADME: Absorption, Distribution, Metabolism, and Excretion
atm: atmosphere
ATSDR: Agency for Toxic Substances and Disease Registry
BCF: bioconcentration factor
BSC: Board of Scientific Counselors
C: Centigrade
CDC: Centers for Disease Control
CEL: Cancer Effect Level
CERCLA: Comprehensive Environmental Response, Compensation, and Liability Act
CFR: Code of Federal Regulations
CLP: Contract Laboratory Program
cm: centimeter
CNS: central nervous system
d: day
DHEW: Department of Health, Education, and Welfare
DHHS: Department of Health and Human Services
DOL: Department of Labor
ECG: electrocardiogram
EEG: electroencephalogram
EPA: Environmental Protection Agency
EKG: see ECG
F: Fahrenheit
F_1_: first filial generation
FAO: Food and Agricultural Organization of the United Nations
FEMA: Federal Emergency Management Agency
FIFRA: Federal Insecticide, Fungicide, and Rodenticide Act
fpm: feet per minute
ft: foot
FR: Federal Register
g: gram
GC: gas chromatography
gen: generation
HPLC: high-performance liquid chromatography
hr: hour
IDLH: Immediately Dangerous to Life and Health
IARC: International Agency for Research on Cancer
ILO: International Labor Organization
in: inch
Kd: adsorption ratio
kg: kilogram
kkg: metric ton
K_oc_: organic carbon partition coefficient
K_ow_: octanol-water partition coefficient
L: liter
LC: liquid chromatography
LC_Lo_: lethal concentration, low
LC_50_: lethal concentration, 50% kill
LD_Lo_: lethal dose, low
LD_50_: lethal dose, 50% kill
LOAEL: lowest-observed-adverse-effect level
LSE: Levels of Significant Exposure
m: meter
mg: milligram
min: minute
mL: milliliter
mm: millimeter
mm Hg: millimeters of mercury
mmol: millimole
mo: month
mppcf: millions of particles per cubic foot
MRL: Minimal Risk Level
MS: mass spectrometry
NIEHS: National Institute of Environmental Health Sciences
NIOSH: National Institute for Occupational Safety and Health
NIOSHTIC: NIOSH’s Computerized Information Retrieval System
ng: nanogram
nm: nanometer
NHANES: National Health and Nutrition Examination Survey
nmol: nanomole
NOAEL: no-observed-adverse-effect level
NOES: National Occupational Exposure Survey
NOHS: National Occupational Hazard Survey
NPL: National Priorities List
NRC: National Research Council
NTIS: National Technical Information Service
NTP: National Toxicology Program
OSHA: Occupational Safety and Health Administration
PEL: permissible exposure limit
pg: picogram
pmol: picomole
PHS: Public Health Service
PMR: proportionate mortality ratio
ppb: parts per billion
ppm: parts per million
ppt: parts per trillion
REL: recommended exposure limit
RfD: Reference Dose
RTECS: Registry of Toxic Effects of Chemical Substances
sec: second
SCE: sister chromatid exchange
SIC: Standard Industrial Classification
SMR: standard mortality ratio
STEL: short term exposure limit
STORET: STORAGE and RETRIEVAL
TLV: threshold limit value
TSCA: Toxic Substances Control Act
TRI: Toxics Release Inventory
TWA: time-weighted average
U.S.: United States
UF: uncertainty factor
yr: year
WHO: World Health Organization
wk: week

>: greater than
≥: greater than or equal to
=: equal to
<: less than
≤: less than or equal to
%: percent
α: alpha
β: beta
δ: delta
γ: gamma
μm: micron
μg: microgram