# 9 REFERENCES

* Not cited in text

Abdel-Rahman SZ, Ammenheuser MM, Omiecinski CJ, . 2005. Variability in human sensitivity to 1,3-butadiene: Influence of polymorphisms in the 5’-flanking region of the microsomal epoxide hydrolase gene (EPHX1). Toxicol Sci 85(1):624–631.15716486
Abdel-Rahman SZ, Ammenheuser MM, Ward JB. 2001. Human sensitivity to 1,3-butadiene: Role of microsomal epoxide hydrolase polymorphisms. Carcinogenesis 22(3):415–423.11238181
Abdel-Rahman SZ, El-Zein RA, Ammenheuser MM, . 2003. Variability in human sensitivity to 1,3-butadiene: Influence of the allelic variants of the microsomal epoxide hydrolase gene. Environ Mol Mutagen 41(2):140–146.12605384
ACGIH. 2008. 1,3-Butadiene. In: Threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
Adam T, Mitsche S, Streibel T, . 2006. Puff-by-puff resolved characterisation of cigarette mainstream smoke by single photon ionisation (SPI)-time-of-flight mass spectrometry (TOFMS): Comparison of the 2R4F research cigarette and pure Burley, Virginia, Oriental and Maryland tobacco cigarettes. Anal Chim Acta 572(2):219–229.17723481
Adinolfi M. 1985. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol 27(4):532–537.4029526
Adler ID, Filser J, Gonda H, . 1998. Dose response study for 1,3-butadiene-induced dominant lethal mutations and heritable translocations in germs cells of male mice. Mutat Res 397(1):85–92.9463555
Adler ID, Filser JG, Gassner P, . 1995a. Heritable translocations induced by inhalation exposure of male mice to 1,3-butadiene. Mutat Res 347(3–4):121–127.7565902
*Adler ID, Kliesch U, Tiveron C, . 1995b. Clastogenicity of diepoxybutane in bone marrow cells and male germ cells of mice. Mutagenesis 10(6):535–541.8596474
Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
Agency for Toxic Substances and Disease Registry. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry, Division of Toxicology, Atlanta, GA. Fed Regist 54(174):37618–37634.
AIChE. 2000. 1,3-Butadiene. C4H6. In: Physical and thermodynamic properties of pure chemicals. American Institute of Chemical Engineers, Design Institute for Physical Property Data. Philadelphia, PA: Taylor and Francis.
AIHA. 2008. Emergency Response Planning Guidelines (ERPG). Fairfax, VA: American Industrial Hygiene Association. http://www.aiha.org/1documents/Committees/ERP-erpglevels.pdf. May 19, 2009.
Albertini RJ, Carson ML, Kirman CR, . 2010. 1,3-Butadiene: II. Genotoxicity profile. Crit Rev Toxicol 40(Suppl 1):12–73.20868267
Albertini RJ, Sram RJ, Vacek PM, . 2001. Biomarkers for assessing occupational exposures to 1,3-butadiene. Chem Biol Interact 135–136:429–453.
Albertini RJ, Sram RJ, Vacek PM, . 2007. Molecular epidemiological studies in 1,3-butadiene exposed Czech workers: Female-male comparisons. Chem Biol Interact 166(1–3):63–77.16949064
Albrecht OE, Filser JG, Neumann HG. 1993. Biological monitoring of 1,3-butadiene: Species differences in haemoglobin binding in rat and mouse. IARC Sci Publ 127:135–142.
Altman PL, Dittmer DS. 1974. Biological handbooks: Biology data book. Vol. III. 2nd ed. Bethesda, MD: Federation of American Societies of Experimental Biology.
American Chemical Society. 2007. United States synthetic rubber program, 1939-1945. American Chemical Society. http://acswebcontent.acs.org/landmarks/landmarks/rbb/index.html. May 29, 2009.
Ammenheuser MM, Bechtold WE, Abdel-Rahman SZ, . 2001. Assessment of 1,3-butadiene exposure in polymer production workers using HPRT mutations in lymphocytes as a biomarker. Environ Health Perspect 109(12):1249–1255.11748032
Amoore JE, Hautala E. 1983. Odor as an aid to chemical safety: Odor thresholds compared with threshold limit values and volatilities for 214 industrial chemicals in air and water dilution. J Appl Toxicol 3(6):272–290.6376602
Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, and replacement. New York, NY: Marcel Dekker, Inc., 9–25.
Andersen ME, Clewell HJ, Gargas ML, . 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87(2):185–205.3824380
Anderson D, Edwards AJ, Brinkworth MH, . 1996. Male-mediated F_1_ effects in mice exposed to 1,3-butadiene. Toxicology 113(1–3):120–127.8901891
Anderson D, Hughes JA, Edwards AJ, . 1998. A comparison of male-mediated effects in rats and mice exposed to 1,3-butadiene. Mutat Res 397(1):77–84.9463554
Anttinen-Klemetti T, Vaaranrinta R, Mutanen P, . 2006. Inhalation exposure to 1,3-butadiene and styrene in styrene-butadiene copolymer production. Int J Hyg Environ Health 209(2):151–158.16503301
Arce GT, Vincent DR, Cunningham MJ, . 1989. The in vitro and in vivo genotoxicity of 1,3-butadiene and metabolites. Haskell Laboratory for Toxicology and Industrial Medicine, E.I. Du Pont de Nemours and Company, Inc.
Atkinson R. 1989. Kinetics and mechanisms of the gas-phase reactions of the hydroxyl radical with organic compounds. J Phys Chem Ref Data 1:110.
Atkinson R, Carter WPL. 1984. Kinetics and mechanisms of gas-phase reactions of ozone with organic compounds under atmospheric conditions. Chem Rev 84:437–470.
Atkinson R, Aschmann SM, Winer AM, . 1984. Kinetics of the gas-phase reactions of NO³ radicals with a series of dialkenes, cycloaklenes, and monoterpenes at 295 ± 1K. Environ Sci Technol 18:370–375.22280087
Au WW, Bechtold WE, Whorton EB, . 1995. Chromosome aberrations and response to γ-ray challenge in lymphocytes of workers exposed to 1,3-butadiene. Mutat Res 334:125–130.7885363
Austin CC, Wang D, Ecobichon DJ, . 2001. Characterization of volatile organic compounds in smoke at municipal structural fires. J Toxicol Environ Health A 63(6):437–458.11482799
Autio K, Renzi L, Catalan J, . 1994. Induction of micronuclei in peripheral blood and bone marrow erythrocytes of rats and mice exposed to 1,3-butadiene by inhalation. Mutat Res 309(2):315–320.7520991
Baker J, Arey J, Atkinson R. 2005. Formation and reaction of hydroxycarbonyls from the reaction of OH radicals with 1,3-butadiene and isoprene. Environ Sci Technol 39(11):4091–4099.15984787
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486.3222488
Bartle KD, Bergstedt L, Novotny M, . 1969. Tobacco chemistry II. Analysis of the gas phase of tobacoo smoke by gas chromatography-mass spectometry. J Chromatogr 45(2):256–263.5359126
Beaudouin R, Micallef S, Brochot C. 2010. A stochastic whole-body physiologically based pharmacokinetic model to assess the impact of inter-individual variability on tissue dosimetry over the human lifespan. Regul Toxicol Pharmacol 57(1):103–116.20122977
Bechtold WE, Strunk MR, Chang I, . 1994. Species differences in urinary butadiene metabolites: Comparisons of metabolite ratios between mice, rats, and humans. Toxicol Appl Pharmacol 127:44–49.8048052
Begemann P, Sram RJ, Neumann HG. 2001a. Hemoglobin adducts of epoxybutene in workers occupationally exposed to 1,3-butadiene. Arch Toxicol 74(11):680–687.11218044
Begemann P, Upton PB, Ranasinghe A, . 2001b. Hemoglobin adducts as biomarkers of 1,3-butadiene in occupationally low exposed Italian workers and a few diesel-exposed miners. Chem Biol Interact 135–136:675–678.
Berger GS, ed. 1994. Epidemiology of endometriosis. In: Endometriosis: Modern surgical management of endometriosis. New York, NY: Springer-Verlag, 3–7.
Bernardini S, Hirvonen A, Pelin K, . 1998. Induction of sister chromatid exchange by 1,2-epoxy-3-butene in cultured human lymphocytes: Influence of GSTT1 genotype. Carcinogenesis 19(2):377–380.9498293
Bevan C, Stadler JC, Elliott GS, . 1996. Subchronic toxicity of 4-vinylcyclohexene in rats and mice by inhalation exposure. Fundam Appl Toxicol 32(1):1–10.8812199
Biemer JJ. 1983. The preleukemic syndrome. Ann Clin Lab Sci 13(2):156–162.6574723
Blomberg L, Widmark G. 1975. Separation of fresh tobacco on a packed polar gas chromatographic column prior to on-line analysis by gas chromatography-mass spectometry using a non-polar capillary column. J Chromatogr 106(1):59–71.1150794
Bois FY, Smith TJ, Gelman A, . 1999. Optimal design for a study of butadiene toxicokinetics in humans. Toxicol Sci 49:213–224.10416266
Bolt HM, Filser JG, Stormer F. 1984. Inhalation pharmacokinetics based on gas uptake studies. V. Comparative pharmacokinetics of ethylene and 1,3-butadiene in rats. Arch Toxicol 55:213–218.6517696
Bolt HM, Schmiedel G, Filser JG, . 1983. Biological activation of 1,3-butadiene to vinyl oxirane by rat liver microsomes and expiration of the reactive metabolite by exposed rats. J Cancer Res Clin Oncol 106:112–116.6630281
Bond JA, Csanady GA, Leavens T, . 1993. Research strategy for assessing target tissue dosimetry of 1,3-butadiene in laboratory animals and humans. IARC Sci Publ (127):45–55.8070886
Bond JA, Dahl AR, Henderson RF, . 1986. Species differences in the disposition of inhaled butadiene. Toxicol Appl Pharmacol 84(3):617–627.3726881
Bond JA, Dahl AR, Henderson RF, . 1987. Species differences in the distribution of inhaled butadiene in tissues. Am Ind Hyg Assoc J 48(10):867–872.3687732
Bond JA, Himmelstein MW, Seaton M, . 1996. Metabolism of butadiene by mice, rats, and humans: A comparison of physiologically based toxicokinetic model predictions and experimental data. Toxicology 113(1–3):48–54.8901882
*Bond JA, Martin OS, Birnbaum LS, . 1988. Metabolism of 1,3-butadiene by lung and liver microsomes of rats and mice repeatedly exposed by inhalation to 1,3-butadiene. Toxicol Lett 44:143–151.3188072
Boogaard PJ, van Sittert NJ, Megens HJ. 2001a. Urinary metabolites and haemoglobin adducts as biomarkers of exposure to 1,3-butadiene: A basis for 1,3-butadiene cancer risk assessment. Chem Biol Interact 135–136:695–701.
Boogaard PJ, van Sittert NJ, Watson WP, . 2001b. A novel DNA adduct, originating from 1,2-epoxy-3,4-butanediol, is the major DNA adduct after exposure to [2,3-^14^C]-1,3-butadiene,[4-^14^C]-1,2-epoxy-3-butane. Chem Biol Interact 135–136:687–693.
Boysen G, Georgieva NI, Bordeerat NK, . 2012. Formation of 1,2:3,4-diepoxybutane-specific hemoglobin adducts in 1,3-butadiene exposed workers. Toxicol Sci 125:30–40.22003190
Boysen G, Georgieva NI, Upton PB, . 2004. Analysis of diepoxide-specific cyclic N-terminal globin adducts in mice and rats after inhalation exposure to 1,3-butadiene. Cancer Res 64(23):8517–8520.15574756
Brinkworth MH, Anderson D, Hughes JA, . 1998. Genetic effects of 1,3-butadiene on the mouse testis. Mutat Res 397(1):67–75.9463553
Brochot C, Bois FY. 2005. Use of a chemical probe to increase safety for human volunteers in toxicokinetic studies. Risk Anal 25(6):1559–1571.16506982
Brochot C, Smith TJ, Bois FY. 2007. Development of a physiologically based toxicokinetic model for butadiene and four major metabolites in humans: Global sensitivity analysis for experimental design issues. Chem Biol Interact 167(3):168–183.17397815
Broderick BM, Marnane IS. 2002. A comparison of the C_2_-C_9_ hydrocarbon compositions of vehicle fuels and urban air in Dublin, Ireland. Atmos Environ 36:975–986.
Bronstein AC, Currance PL. 1988. Emergency care for hazardous materials exposure. St. Louis, MO: C.V. Mosby Company, 226–227.
Brunnemann KD, Kagan MR, Cox JE, . 1990. Analysis of 1,3-butadiene and other selected gas-phase components in cigarette mainstream and sidestream smoke by gas chromatography-mass selective detection. Carcinogenesis 11(10):1863–1868.2208599
Carmella SG, Chen M, Han S, . 2009. Effects of smoking cessation on eight urinary tobacco carcinogen and toxicant biomarkers. Chem Res Toxicol 22(4):734–741.19317515
Carpenter CP, Shaffer CB, Weil CS, . 1944. Studies on the inhalation of 1:3-butadiene; with a comparison of its narcotic effect with benzol, toluol, and styrene, and a note on the elimination of styrene by the human. J Ind Hyg Toxicol 26:69–78.
Carrieri M, Bartolucci GB, Livieri M, . 2009. Quantitative determination of the 1,3-butadiene urinary metabolite 1,2-dihydroxybutyl mercapturic acid by high-performance liquid chromatography/tandem mass spectrometry using polynomial calibration curves. J Chromatogr B Analyt Technol Biomed Life Sci 877:1388–1393.
Case RAM, Hosker ME. 1954. Tumour of the urinary bladder as an occupational disease in the rubber industry in England and Wales. Br J Prev Soc Med 8:39–50.13160351
Checkoway H, Williams TM. 1982. A hematology survey of workers at a styrene-butadiene synthetic rubber manufacturing plant. Am Ind Hyg Assoc J 43:164–169.7064811
Chemical Market Reporter. 2006. Chemical profile: Butadiene. Chem Market Rep May 22–28 2006:34.
Chemical Week. 2008. Product focus: Butadiene. Chem Week March 10:31.
ChemID Plus Advanced. 2009. 1,3-Butadiene. ChemIDplus. Bethesda, MD: U.S. National Library of Medicine. http://chem.sis.nlm.nih.gov/chemidplus/. June 1, 2009.
Cheng H, Sathiakumar N, Graff J, . 2007. 1,3-Butadiene and leukemia among synthetic rubber industry workers: Exposure-response relationships. Chem Biol Interact 166(1–3):15–24.17123495
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Cochrane JE, Skopek TR. 1993. Mutagenicity of 1,3-butadiene and its epoxide metabolites in human TK6 cells and in splenic T cells isolated from exposed B6C3F_1_ mice. In: Sorsa M, Peltonen K, Vainio H, ., eds. Butadiene and styrene: Assessment of healh hazards. IARC Scientific Publications No. 127. Lyon, France: International Agency for Research on Cancer, 195–204.
Counts ME, Hsu FS, Tewes FJ. 2006. Development of a commercial cigarette “market map” comparison methodology for evaluating new or non-conventional cigarettes. Regul Toxicol Pharmacol 46:225–242.16989926
Cowles SR, Tsai SP, Snyder PJ, . 1994. Mortality, morbidity, and haematological results from a cohort of long-term workers involved in 1,3-butadiene monomer production. Occup Environ Med 51(5):323–329.8199682
Crouch CN, Pullinger DH, Gaunt IF. 1979. Inhalation toxicity studies with 1,3-butadiene 2. 3 month toxicity study in rats. Am Ind Hyg Assoc J 40:796–802.517438
Csanady GA, Guengerich FP, Bond JA. 1992. Comparison of the biotransformation of 1,3-butadiene and its metabolite, butadiene monoepoxide, by hepatic and pulmonary tissues from humans, rats and mice. Carcinogenesis 13(7):1143–1153.1638680
Csanady GA, Kreuzer PE, Baur C, . 1996. A physiological toxicokinetic model for 1,3-butadiene in rodents and man: Blood concentrations of 1,3-butadiene, its metabolically formed epoxides, and of haemoglobin adducts–relevance of glutathione depletion. Toxicology 113(1–3):300–305.8901913
Cunningham MJ, Choy WN, Arce GT, . 1986. In vivo sister chromatid exchange and micronucleus induction studies with 1,3-butadiene in B6C3F_1_ mice and Sprague-Dawley rats. Mutagenesis 1(6):449–452.3331684
Currance PL, Clements B, Bronstein AC. 2007. Aliphatic hyrdrocarbons and related compounds. In: Honeycutt L, ed. Emergency care for hazardous materials exposure. 3rd ed. St. Louis, MO: MosbyJems, 240–242.
Curren KC, Dann TF, Wang DK. 2006. Ambient air 1,3-butadiene concentrations in Canada (1995-2003): Seasonal, day of week variations, trends, and source influences. Atmos Environ 40:170–181.
Dahl AR, Bechtold WE, Bond JA, . 1990. Species differences in the metabolism and disposition of inhaled 1,3-butadiene and isoprene. Environ Health Perspect 86:65–69.2401273
Dahl AR, Sun JD, Birnbaum LS, . 1991. Toxicokinetics of inhaled 1,3-butadiene in monkeys: Comparison to toxicokinetics in rats and mice. Toxicol Appl Pharmacol 110(1):9–19.1908146
Delzell E, Macaluso M, Sathiakumar N, . 2001. Leukemia and exposure to 1,3-butadiene, styrene and dimethyldithiocarbamate among workers in the synthetic rubber industry. Chem Biol Interact 135–136:515–534.
Delzell E, Sathiakumar N, Hovinga M, . 1996. A follow-up study of synthetic rubber workers. Toxicology 113(1–3):182–189.8901897
de Meester C. 1988. Genotoxic properties of 1,3-butadiene. Mutat Res 195(104):273–281.3283543
de Meester C, Poncelet F, Roberfroid M, . 1978. Mutagenicity of butadiene and butadiene monoxide. Biochem Biophys Res Commun 80(2):298–305.341894
de Meester C, Poncelet F, Roberfroid M, . 1980. The mutagenicity of butadiene towards Salmonella typhimurium. Toxicol Lett 6(3):125–130.6996220
Deutschmann S, Laib RJ. 1989. Concentration-dependent depletion of non-protein sulfhydryl (NPSH) content in lung, heart and liver tissues of rats and mice after acute inhalation exposure to butadiene. Toxicol Lett 45:175–183.2919398
Divine BJ. 1989. An update on mortality among workers at a butadiene facility—preliminary results. Report by Texaco Inc., Houston, TX.
Divine BJ. 1990. An update on mortality among workers at a 1,3-butadiene facility — preliminary results. Environ Health Perspect 86:119–128.2401252
Divine BJ, Hartman CM. 1996. Mortality update of butadiene production workers. Toxicology 113(1–3):169–181.8901896
Divine BJ, Hartman CM. 2001. A cohort mortality study among workers at a 1,3 butadiene facility. Chem Biol Interact 135–136:535–553.
Divine BJ, Wendt JK, Hartman CM. 1993. Cancer mortality among workers at a butadiene production facility. In: Sorsa M, Peltonen K, Vainio H, ., eds. Butadiene and styrene: Assessment of healh hazards. IARC Scientific Publications No. 127. Lyon, France: International Agency for Research on Cancer, 345–362.
DOE/NTP. 1987a. Inhalation developmental toxicology studies of 1,3-butadiene in the rat. Final report. Richland, WA: U.S. Department of Energy. National Toxicology Program. PNL6414. DE88004186.
DOE/NTP. 1987b. Inhalation developmental toxicology studies: Teratology study of 1,3-butadiene in mice. Final report. U.S. Department of Energy. National Toxicology Program. PNL6412. DE88004187.
DOE/NTP. 1988a. Sperm-head morphology study in B6C3F_1_ mice following inhalation exposure to 1,3-butadiene. Final technical report. Richland, WA: U.S. Department of Energy. National Toxicology Program. PNL6459. DE88008620.
DOE/NTP. 1988b. Dominant lethal study in CD-1 mice following inhalation exposure to 1,3-butadiene: Final technical report. Richmond, WA: U.S. Department of Energy. National Toxicology Program. PNL6545. DE88010185.
Doerr JK, Hollis EA, Sipes IG. 1996. Species difference in the ovarian toxicity of 1,3-butadiene epoxides in B6C3F_1_ mice and Sprague-Dawley rats. Toxicology 113:128–136.8901892
Dolnick AA, Potash M. 1948. Butadiene. In: Kirk RE, Othmer DF, eds. Kirk-Othmer encyclopedia of chemical technology. Vol. 2. New York, NY: Interscience Encylcopedia, Inc., 669–674.
Downs TD, Crane MM, Kim KW. 1987. Mortality among workers at a butadiene facility. Am J Ind Med 12:311–329.3674024
Duescher RJ, Elfarra AA. 1994. Human liver microsomes are efficient catalysts of 1,3-butadiene oxidation: Evidence for major roles by cytochromes P450 2A6 and 2E1. Arch Biochem Biophys 311(2):342–349.8203896
Elfarra AA, Krause RJ, Kemper RA. 2001. Cellular and molecular basis for species, sex and tissue differences in 1,3-butadiene metabolism. Chem Biol Interact 135–136:239–248.
Elfarra AA, Krause RJ, Selzer RR. 1996. Biochemistry of 1,3-butadiene metabolism and its relevance to 1,3-butadiene-induced carcinogenicity. Toxicology 113(1–3):23–30.8901879
EPA. 1978. Interim primary drinking water regulations. U.S. Environmental Protection Agency. Fed Regist 43:29135–29150.
EPA. 1982. Methods for organic chemical analysis of municipal and industrial wastewater. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Monitoring and Support Laboratory. EPA6001482057.
EPA. 1985. Mutagenicity and carcinogenicity assessment of 1,3-butadiene. Washington, DC: U.S. Environmental Protection Agency. EPA600885004F.
EPA. 1986. Methods for the determination of organic compounds in finished drinking water and raw source water. Cincinnati, OH: U.S. Environmental Protection Agency, Physical and Chemical Methods Branch.
EPA. 1988a. Guidelines establishing test procedures for the analysis of pollutants. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 1:36, 249–267.
*EPA 1988b. Protection of environment. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 355:182–191.
EPA. 1994. Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry. Washington, DC: U.S. Environmental Protection Agency. EPA600890066F.
EPA. 1997. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. EPA630R96012.
EPA. 1999a. Compendium of methods for the determination of toxic organic compounds in ambient air. Second edition. Compendium method TO-15. Determination of volatile organic compounds (VOCs) in air collected in specially-prepared canisters and analyzed by gas chromatography/mass spectrometry (GC/MS). Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development. EPA625R96010b.
EPA. 1999b. Compendium of methods for determination of toxic organic compounds in ambient air. Second edition. Compendium method TO-14A. Determination of volatile organic compounds (VOCs) in ambient air using specially prepared canisters with subsequent analysis by gas chromatography. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development. EPA625R96010b
EPA. 2002. Health assessment of 1,3-butadiene. Washington, DC: U.S. Environmental Protection Agency. EPA600P98001F.
EPA. 2003a. Estimate background concentrations for the national-scale air toxics assessment. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards.
EPA. 2003b. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency. Office of Ground Water and Drinking Water, http://www.epa.gov/safewater/contaminants/index.html. May 19, 2009.
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency, Office of Environmental Information. EPA260B05001.
EPA. 2006a. Drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency, Office of Water. EPA822R04005. http://epa.gov/waterscience/criteria/drinking/. May 19, 2009.
EPA. 2006b. National recommended water quality criteria. Washington, DC: U.S. Environmental Protection Agency. Office of Water, Office of Science and Technology, http://www.epa.gov/waterscience/criteria/wqcriteria.html. May 11, 2009.
EPA. 2008. 2005 National emissions inventory data & documentation. National Emissions Inventory. U.S. Environmental Protection Agency. http://www.epa.gov/ttn/chief/net/2005inventory.html. May 26, 2009.
EPA. 2009a. Acute exposure guideline levels (AEGLs). Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/oppt/aegl/. May 19, 2009.
EPA. 2009b. Hazardous air pollutants. Clean Air Act. U.S. Environmental Protection Agency. United States Code. 42 USC 7412. http://www.epa.gov/ttn/atw/orig189.html. May 19, 2009.
EPA. 2009c. Regulated toxic substances and threshold quantities for accidental release prevention. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 68.130. http://www.epa.gov/lawsregs/search/40cfr.html. May 20, 2009.
EPA. 2009d. Superfund, emergency planning, and community right-to-know programs. Designation, reportable quantities, and notifications. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4. http://www.epa.gov/lawsregs/search/40cfr.html. May 20, 2009.
EPA. 2009e. Superfund, emergency planning, and community right-to-know programs. Toxic chemical release reporting. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.65. http://www.epa.gov/lawsregs/search/40cfr.html. May 11, 2009.
Evelo CTA, Oostendorp JGM, ten Berge WF, . 1993. Physiologically based toxicokinetic modeling of 1,3-butadiene lung metabolism in mice becomes more important at low does. Environ Health Perspect 101(6):496–502.8137778
FDA. 2008. Everything added to food in the United States (EAFUS). Washington, DC: U.S. Food and Drug Administration. http://vm.cfsan.fda.gov/~dms/eafus.html. May 19, 2009.
FEDRIP. 2009. Federal Research in Progress Database. Springfield, VA: National Technical Information Service.
Filser JG, Bolt HM. 1984. Inhalation pharmacokinetics based on gas uptake studies. VI. Comparative evaluation of ethylene oxide and butadiene monoxide as exhaled reactive metabolites of ethylene and 1,3-butadiene in rats. Arch Toxicol 55(4):219–223.6517697
Filser JG, Bhowmik S, Faller TH, . 2010. Quantitative investigation on the metabolism of 1,3-butadiene and of its oxidized metabolites in once-through perfused livers of mice and rats. Toxicol Sci 114(1):25–37.20007191
Filser JG, Faller TH, Bhowmik S, . 2001. First-pass metabolism of 1,3-butadiene in once-through perfused livers of rats and mice. Chem Biol Interact 135–136:249–265.
Filser JG, Hutzler C, Meischner V, . 2007. Metabolism of 1,3-butadiene to toxicologically relevant metabolites in single-exposed mice and rats. Chem Biol Interact 166(1–3):93–103.16616907
Filser JG, Johanson G, Kessler W, . 1993. A pharmacokinetic model to describe toxicokinetic interactions between 1,3-butadiene and styrene in rats: Predictions for human exposure. In: Sorsa M, Peltonen K, Vainio H, ., eds. Butadiene and styrene: Assessment of health hazards. IARC Scientific Publications No. 127. Lyon, France: International Agency for Research on Cancer, 65–78.
Fomon SJ. 1966. Body composition of the infant: Part I: The male reference infant. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246
Fomon SJ, Haschke F, Ziegler EE, . 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35(Suppl 5):1169–1175.7081099
Fox AJ, Lindars DC, Owen R. 1974. A survey of occupational cancer in the rubber and cablemaking industries: Results of five-year analysis, 1976-71. Br J Ind Med 31(2):140–151.4830765
Fustinoni S, Perbellini L, Soleo L, . 2004. Biological monitoring in occupational exposure to low levels of 1,3-butadiene. Toxicol Lett 149(1–3):353–360.15093281
Georgieva NI, Boysen G, Bordeerat N, . 2010. Exposure-response of 1,2:3,4-diepoxybutane-specific N-terminal valine adducts in mice and rats after inhalation exposure to 1,3-butadiene. Toxicol Sci 115(2):322–329.20176624
Giwercman A, Carlsen E, Keiding N, . 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect 101(Suppl 2):65–71.7902273
Goggin M, Swenberg JA, Walker VE, . 2009. Molecular dosimetry of 1,2,3,4-diepoxybutane-induced DNA — DNA cross-links in B6C3F_1_ mice and F344 rats exposed to 1,3-butadiene by inhalation. Cancer Res 69(6):2479–2486.19276346
Graff JJ, Sathlakumar N, Macaluso M, . 2005. Chemical exposures in the synthetic rubber industry and lymphohematopoietic cancer mortality. J Occup Med 47:916–932.
Graff JJ, Sathiakumar N, Macaluso M, . 2009. The effect of uncertainty in exposure estimation on the exposure-response relation between 1,3-butadiene and leukemia. Int J Environ Res Public Health 6(9):2436–2455.19826555
Graham LA, Noseworthy L, Fugler D, . 2004. Contribution of vehicle emissions from an attached garage to residential indoor air pollution levels. J Air Waste Manage Assoc 54(5):563–584.
Grant RL, Haney J, Curry AL, . 2010. A chronic reference value for 1,3-butadiene based on an updated noncancer toxicity assessment. J Toxicol Environ Health B Crit Rev 13(6):460–475.20711928
Grant RL, Leopold V, McCant D, . 2007. Spatial and temporal trend evaluation of ambient concentrations of 1,3-butadiene and chloroprene in Texas. Chem Biol Interact 166(1–3):44–51.17011534
Green T, Toghill A, Moore R. 2001. The influence of co-exposure to dimethyldithiocarbamate on butadiene metabolism. Chem Biol Interact 135–136:585–598.
Grub J, Loser E. 2005. Butadiene. In: Ullmann’s encyclopedia of industrial chemistry, 1–17. http://mrw.interscience.wiley.com/emrw/9783527306732/ueic/article/a04_431/current/pdf. May 31, 2009.
Gustafson P, Barregard L, Strandberg B, . 2007. The impact of domestic wood burning on personal, indoor and outdoor levels of 1,3-butadiene, benzene, formaldehyde and acetaldehyde. J Environ Monit 9(1):23–32.17213939
Guzelian PS, Henry CJ, Olin SS. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences and Press Institute Press.
Hallberg LM, Bechtold WE, Grady J, . 1997. Abnormal DNA repair activities in lymphocytes of workers exposed to 1,3-butadiene. Mutat Res 383(3):213–221.9164482
Hansch C, Leo A, Hoekman D. 1995. Exploring QSAR hydrophobic, electronic, and steric constants. Washington, DC: American Chemical Society, 8.
Hayes RB, Xi L, Bechtold WE, . 1996. hprt Mutation frequency among workers exposed to 1,3-butadiene in China. Toxicology 113(1–3):100–105.8901888
Hayes RB, Zhang L, Swenberg JA, . 2001. Markers for carcinogenicity among butadiene-polymer workers in China. Chem Biol Interact 135–136:455–464.
Hayes RB, Zhang L, Yin S, . 2000. Genotoxic markers among butadiene polymer workers in China. Carcinogenesis 21(1):55–62.10607734
HazDat. 2007. 1,3-Butadiene. HazDat Database: ATSDR’s Hazardous Substance Release and Health Effects Database. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
Health Canada. 2000. Canadian Environmental Protection Act, 1999. Priority substances list health assessment: 1,3-Butadiene. Health Canada. Environment Canada. Minister of Public Works and Governmnent Services. http://www.hc-sc.gc.ca/ewh-semt/pubs/contaminants/psl2-lsp2/1_3_butadiene/index-eng.php. July 9, 2009.
HEI. 2000. 1,3-Butadiene: cancer, mutations, and adducts. Number 92. Cambridge, MA: Health Effects Institute.
HEI. 2003. Biomarkers in Czech workers exposed to 1,3-butadiene: A transitional epidemiologic study. Number 116. Boston, MA: Health Effects Institute.
HEI. 2006. An updated study of mortality among North American synthetic rubber industry workers. Number 132. Boston, MA: Health Effects Institute.
Henderson RF, Thornton-Manning JR, Bechtold WE, . 1996. Metabolism of 1,3-butadiene: Species differences. Toxicology 113(1–3):17–22.8901878
Hendricks WD, Schultz GR. 1986. A sampling and analytical method for monitoring low ppm air concentrations of 1,3-butadiene. Appl Ind Hyg 1:186–189.
Higashino H, Mita K, Yoshikado H, . 2007. Exposure and risk assessment of 1,3-butadiene in Japan. Chem Biol Interact 166(1–3):52–62.17092494
Himmelstein MW, Acquavella JF, Recio L, . 1997. Toxicology and epidemiology of 1,3-butadiene. Crit Rev Toxicol 27(1):1–108.9115622
Himmelstein MW, Asgharian B, Bond JA. 1995. High concentrations of butadiene epoxides in livers and lungs of mice compared to rats exposed to 1,3-butadiene. Toxicol Appl Pharmacol 132(2):281–288.7785055
Himmelstein MW, Turner MJ, Asgharian B, . 1994. Comparison of blood concentrations of 1,3-butadiene and butadiene epoxides in mice and rats exposed to 1,3-butadiene by inhalation. Carcinogenesis 15(8):1479–1486.8055623
Himmelstein MW, Turner MJ, Asgharian B, . 1996. Metabolism of 1,3-butadiene: Inhalation pharmacokinetics and tissue dosimetry of butadiene epoxides in rats and mice. Toxicology 113(1–3):306–309.8901914
Hoel DG, Davis DL, Miller AB, . 1992. Trends in cancer mortality in 15 industrialized countries, 1969-1986. J Natl Cancer Inst 84(5):313–320.1738181
Hong HH, Devereux TR, Melnick RL, . 2000. Mutations of ras protooncogenes and p53 tumor suppressor gene in cardiac hemangiosarcomas from B6C3F_1_ mice exposed to 1,3-butadiene for 2 years. Toxicol Pathol 28(4):529–534.10930038
Hou CT, Patel R, Laskin AI, . 1979. Microbial oxidation of gaseous hydrocarbons: Epoxidation of C_2_ to C_4_ n-alkenes by methylotrophic bacteria. Appl Environ Microbiol 38:127–134.39502
Hou CT, Patel R, Laskin AI, . 1983. Epoxidation of short-chain alkenes by resting-cell suspensions of propane-grown bacteria. Appl Environ Microbiol 46:171–177.16346338
HSDB. 2009. 1,3-butadiene. Hazardous Substances Data Bank. http://toxnet.nlm.nih.gov/cgi-bin/sis/htmlgen?HSDB. April 7, 2009.
Hughes K, Meek ME, Walker M, . 2003. 1,3-Butadiene: Exposure estimation, hazard characterization, and exposure-response analysis. J Toxicol Environ Health B Crit Rev 6(1):55–83.12587254
Hurst HE. 2007. Toxicology of 1,3-butadiene, chloroprene, and isoprene. Rev Environ Contam Toxicol 189:131–179.17193739
IARC. 2009. Agents reviewed by the IARC Monographs. Volumes 1–99. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Classification/index.php. May 19, 2009.
ICIS. 2009. Butadiene uses and market data. http://www.icis.com/v2/chemicals/9075172/butadiene/uses.html. June 1, 2009.
IRIS. 2012. 1,3-Butadiene. Washington, DC: Integrated Risk Information System. http://www.epa.gov/iris/subst/index.html. September 5, 2012.
Irons RD, Pyatt DW. 1998. Dithiocarbamates as potential confounders in butadiene epidemiology. Carcinogenesis 19(4):539–542.9600335
Irons RD, Oshimura M, Barrett JC. 1987b. Chromosome aberrations in mouse bone marrow cells following in vivo exposure to 1,3-butadiene. Carcinogenesis 8(11):1711–1714.3664963
Irons RD, Smith CN, Stillman WS, . 1986a. Macrocytic-megaloblastic anemia in male B6C3F_1_ mice following chronic exposure to 1,3-butadiene. Toxicol Appl Pharmacol 83(1):95–100.3952753
Irons RD, Smith CN, Stillman WS, . 1986b. Macrocytic-megaloblastic anemia in male NIH Swiss mice following repeated exposure to 1,3-butadiene. Toxicol Appl Pharmacol 85(3):450–455.3020740
*Irons RD, Stillman WS, Cloyd MW. 1987a. Selective activation of endogenous ecotropic retrovirus in hematopoietic tissues of B6C3F_1_ mice during the preleukemic phase of 1,3-butadiene exposure. Virology 161(2):457–462.2825417
Irons RD, Stillman WS, Pyatt DW, . 2001. Comparative toxicity of dithiocarbamates and butadiene metabolites in human lymphoid and bone marrow cells. Chem Biol Interact 135–136:615–625.
Irvine LFH. 1981. 1,3-Butadiene: Inhalation teratogenicity study in the rat. Final report. Harrogate, England: Hazleton Laboratories Europe Ltd. OTS050545.
*Jackson MA, Stack HF, Rice JM, . 2000a. A review of the genetic and related effects of 1,3-butadiene in rodents and humans. Mutat Res 463(3):181–213.11018742
Jackson TE, Lilly PD, Recio L, . 2000b. Inhibition of cytochrome P450 2E1 decreases, but does not eliminate, genotoxicity mediated by 1,3-butadiene. Toxicol Sci 55(2):266–273.10828257
Jauhar PP, Henika PR, Macgregor JT, . 1988. 1,3-Butadiene: Induction of micronucleated erythrocytes in the peripheral blood of B6C3F_1_ mice exposed by inhalation for 13 weeks. Mutat Res 209(3–4):171–176.3193981
Jelitto B, Vangala RR, Laib RJ. 1989. Species differences in DNA damage by butadiene: Role of diepoxybutane. Arch Toxicol Suppl 13:246–249.2774939
Johanson G, Filser JG. 1993. A physiologically based pharmacokinetic model for butadiene and its metabolite butadiene monoxide in rat and mouse and its significance for risk extrapolation. Arch Toxicol 67(3):151–163.8494494
Johanson G, Filser JG. 1996. PBPK model for butadiene metabolism to epoxides: Quantitative species differences in metabolism. Toxicology 113(1–3):40–47.8901881
Jones B, Harris RL. 1983. Calculation of time-weighted average concentrations: A computer mapping application. Am Ind Hyg Assoc J 44:795–801.
Junk GA, Ford CS. 1980. A review of organic emissions from selected combustion processes. Chemosphere 9:187–230.
Kelsey KT, Wiencke JK, Ward J, . 1995. Sister-chromatid exchanges, glutathione S-transferase θ deletion and cytogenetic sensitivity to diepoxybutane in lymphocytes from butadiene monomer production workers. Mutat Res 335(3):267–273.8524342
Kennedy CH, Catallo WJ, Wilson VL, . 2009. Combustion products of 1,3-butadiene inhibit catalase activity and induce expression of oxidative DNA damage repair enzymes in human bronchial epithelial cells. Cell Biol Toxicol 25(5):457–470.18685817
*Khalil M, Abudiab M, Ahmed AE. 2007. Clinical evaluation of 1,3-butadiene neurotoxicity in humans. Toxicol Ind Health 23(3):141–146.18220155
Kim SR, Dominici F, Buckley TJ. 2007. Concentrations of vehicle-related air pollutants in an urban parking garage. Environ Res 105(3):291–299.17716646
Kim Y, Hong HH, Lachat Y, . 2005. Genetic alterations in brain tumors following 1,3-butadiene exposure in B6C3F_1_ mice. Toxicol Pathol 33(3):307–312.15814359
Kim YM, Harrad S, Harrison RM. 1999. An improved method for the determination of 1,3-butadiene in nonoccupational environments. Environ Sci Technol 33:4342–4345.
Kim YM, Harrad S, Harrison RM. 2001. Concentrations and sources of VOCs in urban domestic and public microenvironments. Environ Sci Technol 35(6):997–1004.11347947
Kim YM, Harrad S, Harrison RM. 2002. Levels and sources of personal inhalation exposure to volatile organic compounds. Environ Sci Technol 36(24):5405–5410.12521168
Kirman CR, Grant RL. 2012. Quantitative human health risk assessment for 1,3-butadiene based upon ovarian effects in rodents. Regul Toxicol Pharmacol 62(2):371–384.22100993
Kirman CR, Albertini RA, Gargas ML. 2010b. 1,3-Butadiene: III. Assessing carcinogenic modes of action. Crit Rev Toxicol 40(Suppl 1):74–92.20868268
Kirman CR, Albertini RJ, Sweeney LM, . 2010a. 1,3-Butadiene: I. Review of metabolism and the implications to human health risk assessment. Crit Rev Toxicol 40(Suppl 1):1–11.
Kirshenbaum I. 1978. Butadiene. In: Kirk-Othmer encyclopedia of chemical technology. Vol. 4. New York, NY: John Wiley & Sons, 313–337.
Kligerman AD, DeMarini DM, Doerr CL, . 1999. Comparison of cytogenetic effects of 3,4-epoxy-1-butene and 1,2:3, 4-diepoxybutane in mouse, rat and human lymphocytes following in vitro G_0_ exposures. Mutat Res 439(1):13–23.10029668
Knox EG. 2005. Childhood cancers and atmospheric carcinogens. J Epidemiol Community Health 59:101–105.15650139
Knox EG. 2006. Roads, railways, and childhood cancers. J Epidemiol Community Health 60(2):136–141.16415262
Kohn MC. 1997. The importance of anatomical realism for validation of physiological models of disposition of inhaled toxicants. Toxicol Appl Pharmacol 147:448–458.9439740
Kohn MC, Melnick RL. 1993. Species differences in the production and clearance of 1,3-butadiene metabolites: A mechanistic model indicates predominantly physiological, not biochemical, control. Carcinogenesis 14(4):619–628.8472325
Kohn MC, Melnick RL. 1996. Effects of the structure of a toxicokinetic model of butadiene inhalation exposure on computed production of carcinogenic intermediates. Toxicology 113(1–3):31–39.8901880
Kohn MC, Melnick RL. 2000. The privileged access model of 1,3-butadiene disposition. Environ Health Perspect 108(Suppl 5):911–917.
Kohn MC, Melnick RL. 2001. Physiological modeling of butadiene disposition in mice and rats. Chem Biol Interact 135–136:285–301.
Koivisto P, Peltonen K. 2001. N7-guanine adducts of the epoxy metabolites of 1,3-butadiene in mice lung. Chem Biol Interact 135–136:363–372.
Koturbash I, Scherhag A, Sorrentino J, . 2011b. Epigenetic alterations in liver of C57BL/6J mice after short-term inhalational exposure to 1,3-butadiene. Environ Health Perspect 119(5):635–640.21147608
Koturbash I, Scherhag A, Sorrentino J, . 2011a. Epigenetic mechanisms of mouse inter-strain variability in genotoxicity of the environmental toxicant 1,3-butadiene. Toxicol Sci 122(2):448–456.21602187
Krause RJ, Elfarra AA. 1997. Oxidation of butadiene monoxide to meso- and (+/−)-diepoxybutane by cDNA-expressed human cytochrome P450s and by mouse, rat, and human liver microsomes: evidence for preferential hydration of meso-diepoxybutane in rat and human liver microsomes. Arch Biochem Biophys 337(2):176–184.9016811
Kraybill HF. 1980. Evaluation of public health aspects of carcinogenic/mutagenic biorefractories in drinking water. Prev Med 9:212–218.7383987
Kreiling R, Laib RJ, Bolt HM. 1986a. Alkylation of nuclear proteins and DNA after exposure of rats and mice to carbon-14 1,3-butadiene. Toxicol Lett 30(2):131–136.3705101
Kreiling R, Laib RJ, Bolt HM. 1988. Depletion of hepatic non-protein sulfhydryl content during exposure of rats and mice to butadiene. Toxicol Lett 41(3):209–214.3376148
Kreiling R, Laib RJ, Filser JG, . 1986b. Species differences in butadiene metabolism between mice and rats evaluated by inhalation pharmacokinetics. Arch Toxicol 58(4):235–238.3718226
Kreiling R, Laib RJ, Filser JG, . 1987. Inhalation pharmacokinetics of 1,2-epoxybutene-3 reveal species differences between rats and mice sensitive to butadiene-induced carcinogenesis. Arch Toxicol 61(1):7–11.3439877
Krishnan K, Andersen ME. 1994. Physiologically based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. 3rd ed. New York, NY: Raven Press, Ltd., 149–188.
Krishnan K, Anderson ME, Clewell HJ, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Lahdetie J, Peltonen K, Sjoblom T. 1997. Germ cell mutagenicity of three metabolites of 1,3-butadiene in the rat: Induction of spermatid micronuclei by butadiene mono-, di-, and diolepoxides in vivo. Environ Mol Mutagen 29(3):230–239.9142165
Laib RJ, Filser JG, Kreiling R. 1988. Species differences in butadiene metabolism between mouse and rat. Ann N Y Acad Sci 534:663–670.3389683
Laib RJ, Filser JG, Kreiling R, . 1990. Inhalation pharmacokinetics of 1,3-butadiene and 1,2-epoxybutene-3 in rats and mice. Environ Health Perspect 86:57–63.2401272
Laib RJ, Tucholski M, Filser JG, . 1992. Pharmacokinetic interaction between 1,3-butadiene and styrene in Sprague-Dawley rats. Arch Toxicol 66(5):310–314.1610292
Leavens TL, Bond JA. 1996. Pharmacokinetic model describing the disposition of butadiene and styrene in mice. Toxicology 113(1–3):310–313.8901915
Leavens TL, Farris GM, James RA, . 1997. Genotoxicity and cytotoxicity in male B6C3F_1_ mice following exposure to mixtures of 1,3-butadiene and styrene. Environ Mol Mutagen 29(4):335–345.9212784
Leavens TL, Moss OR, Turner MJ, . 1996. Metabolic interactions of 1,3-butadiene and styrene in male B6C3F1 mice. Toxicol Appl Pharmacol 141(2):628–636.8975788
Leber AP. 2001. Human exposures to monomers resulting from consumer contact with polymers. Chem Biol Interact 135–136:215–220.
Leeder JS, Kearns GL. 1997. Pharmacogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44(1):55–77.9057784
Leiderman LJ, Stillman WS, Shah RS, . 1986. Altered hematopoietic stem cell development in male B6C3F_1_ mice following exposure to 1,3-butadiene. Exp Mol Pathol 44(1):50–56.3948977
Leikin JB, Paloucek FP. 2002. Leikin & Paloucek’s poisoning & toxicology handbook. 3rd ed. Hudson, OH: Lexi-Comp, Inc., 306.
Leung H. 1993. Physiologically-based pharmacokinetic modelling. In: Ballantyne B, Marrs T, Turner P, eds. General and applied toxicology. Vol. 1. New York, NY: Stockton Press, 153–164.
Lewis RJ. 2007. 1,3-Butadiene. In: Lewis RJ, ed. Hawley’s condensed chemical dictionary. 5th ed. New York, NY: John Wiley & Sons, Inc., 190.
Lide DR. 2008. Physical constants of organic compounds. In: Lide DR, ed. CRC handbook of chemistry and physics. 88th ed. New York, NY: CRC Press, 3–72.
Lin YS, Smith TJ, Kelsey KT, . 2001. Human physiologic factors in respiratory uptake of 1,3-butadiene. Environ Health Perspect 109(9):921–926.11673121
Lin YS, Smith TJ, Wypij D, . 2002. Association of the blood/air partition coefficient of 1,3-butadiene with blood lipids and albumin. Environ Health Perspect 110(2):165–168.11836145
Liu S, Ao L, Du B, . 2008. HPRT mutations in lymphocytes from 1,3-butadiene-exposed workers in China. Environ Health Perspect 116:203–208.18288319
Livingston AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4(2–3):301–324.351201
Lofroth G, Burton RM, Forehand L, . 1989. Characterization of environmental tobacco smoke. Environ Sci Technol 23(5):610–614.
Lonneman WA, Namie GR, Bufalini JJ. 1979. Hydrocarbons in Houston air. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA600379018, 36.
Loprieno N, Presciuttini S, Sbrana I, . 1978. Mutagenicity of industrial compounds. VII. Styrene and styrene oxide: II. Point mutations, chromosome aberrations and DNA repair induction analyses. Scand J Work Environ Health 4:169–178.366743
Lovreglio P, Bukvic N, Fustinoni S, . 2006. Lack of genotoxic effect in workers exposed to very low doses of 1,3-butadiene. Arch Toxicol 80(6):378–381.16307232
Lunsford RA. 1987. Comments on sampling and analytical method for monitoring low ppm air concentrations of 1,3-butadiene. Appl Ind Hyg 2:93–94.
Lunsford RA, Gagnon YT. 1987. Use of a backflushable pre-column to maintain the performance of an aluminum oxide porous-layer open-tubular fused silica column for the determination of 1,3-butadiene in air. J High Resolut Chromatogr 10:102–104.
Lyman WJ, Reehl WF, Rosenblatt DH. 1990. In: Handbook of chemical property estimation methods. Washington, DC: American Chemical Society, 15-15 to 15-17.
Ma H, Wood TG, Ammenheuser MM, . 2000. Molecular analysis of hprt mutant lymphocytes from 1,3-butadiene-exposed workers. Environ Mol Mutagen 36(1):59–71.10918361
Macaluso M, Larson R, Delzell E, . 1996. Leukemia and cumulative exposure to butadiene, styrene and benzene among workers in the synthetic rubber industry. Toxicology 113(1–3):190–202.8901898
Macaluso M, Larson R, Lynch J, . 2004. Historical estimation of exposure to 1,3-butadiene, styrene, and dimethyldithiocarbamate among synthetic rubber workers. J Occup Environ Hyg 1(6):371–390.15238328
Madhusree B, Goto S, Ohkubo T, . 2002. Mutagenicity testing of 1,3-butadiene, 1,4-pentadiene-3-ol, isoprene, 2,4-hexadiene, cis- and trans-piperlylene. J Health Sci 48(1):73–78.
Malvoisin E, Roberfroid M. 1982. Hepatic microsomal metabolism of 1,3-butadiene. Xenobiotica 12(2):137–144.7090423
Malvoisin E, Lhoest G, Poncelet F, . 1979. Identification and quantitation of 1,2-epoxybutene-3 as the primary metabolite of 1,3-butadiene. J Chromatogr 178(2):419–425.
Marshall JD, Granvold PW, Hoats AS, . 2006. Inhalation intake of ambient air pollution in California’s South Coast Air Basin. Atmos Environ 40(23):4381–4392.
Matanoski GM, Schwartz L. 1987. Mortality of workers in styrene-butadiene polymer production. J Occup Med 29(8):675–680.3655951
Matanoski GM, Santos-Burgoa C, Schwartz L. 1988. Mortality of a cohort of workers in the styrene-butadiene polymer manufacturing industry 1943-1982 (final report prepared under contract to International Institute of Synthetic Rubber Producers, Inc.). Baltimore, MD: The Johns Hopkins University, School of Hygiene and Public Health.
Matanoski GM, Santos-Burgoa C, Schwartz L. 1990. Mortality of a cohort of workers in the styrene-butadiene polymer manufacturing industry (1943-1982). Environ Health Perspect 86:107–117.2401250
Matanoski GM, C. S-B, Zeger SL, . 1989a. Epidemiologic data related to health effects of 1,3-butadiene. In: Mohn U, ed. Assessment of inhalation hazards: Integration and extrapolation using diverse data. New York, NY: Springer-Verlag, 201–214.
Matanoski GM, Santos-Burgoa C, Zeger SL, . 1989b. Nested case-control study of lymphopoietic cancers in workers in the styrene-butadiene polymer manufacturing industry (final report prepared under contract to International Institute of Synthetic Rubber Producers, Inc.). Baltimore, MD: The Johns Hopkins University, School of Hygiene and Public Health.
Matanoski GM, Schwartz L, Sperrazza J, . 1982. Mortality of workers in the styrene-butadiene rubber polymer manufacturing industry. Baltimore, MD: Johns Hopkins University School of Hygiene and Public Health.
Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74(2–3):135–149.1387742
MCA. 1974. Chemical safety data sheet SD-55. Properties and essential information for safe handling and use of butadiene. Washington, DC: Manufacturing Chemicals Association.
McAuliffe C. 1966. Solubility in water of paraffin, cycloparaffin, olefin, acetylene, cycloolefin, and aromatic hydrocarbons. J Phys Chem 7(4):1267–1275.
McCarthy MC, Hafner HR, Montzka SA. 2006. Background concentrations of 18 air toxics for North America. J Air Waste Manag Assoc 56(1):3–11.16499141
McDonald JD, Bechtold WE, Krone JR . 2004. Analysis of butadiene urinary metabolites by liquid chromatography-triple quadrupole mass spectrometry. J Anal Toxicol 28:168–173.15107146
McMichael AJ, Spirtas R, Gamble JF, . 1976. Mortality among rubber workers: Relationship to specific jobs. J Occup Med 18:178–185.1255279
McMichael AJ, Spirtas R, Kupper LL. 1974. An epidemiologic study of mortality within a cohort of rubber workers, 1964-1972. J Occup Med 16:458–464.4842655
McMichael AJ, Spirtas R, Kupper LL, . 1975. Solvent exposure and leukemia among rubber workers: An epidemiologic study. J Occup Med 17:234–239.1055183
McNeal TP, Breder CV. 1987. Headspace gas chromatographic determination of residual 1,3-butadiene in rubber-modified plastics and its migration from plastic containers into selected foods. J Assoc Off Anal Chem 70:18–21.3558271
Meinhardt TJ, Lemen RA, Crandall MS, . 1982. Environmental epidemiologic investigation of the styrene-butadiene rubber industry. Scand J Work Environ Health 8:250–259.7170621
Melnick R, Huff J, Miller R. 1989. Toxicology and carcinogenicity of 1,3-butadiene. In: Mohn U, ed. Assessment of inhalation hazards: Integration and extrapolation using diverse data. New York, NY: Springer-Verlag, 177–188.
Melnick RL, Huff J, Chou BJ, . 1990a. Carcinogenicity of 1,3-butadiene in C57BL/6 x C3H F_1_ mice at low exposure concentrations. Cancer Res 50(20):6592–6599.2208121
Melnick RL, Huff JE, Roycroft JH, . 1990b. Inhalation toxicology and carcinogenicity of 1,3-butadiene in B6C3F_1_ mice following 65 weeks of exposure. Environ Health Perspect 86:27–36.2401263
Meng Q, Henderson RF, Chen T, . 1999. Mutagenicity of 1,3-butadiene at the Hprt locus of T-lymphocytes following inhalation exposures of female mice and rats. Mutat Res 429(1):107–125.10434027
Meng Q, Singh N, Heflich RH, . 2000. Comparison of the mutations at Hprt exon 3 of T-lymphocytes from B6C3F1 mice and F344 rats exposed by inhalation to 1,3-butadiene or the racemic mixture of 1,2:3,4-diepoxybutane. Mutat Res 464(2):169–184.10648904
Meng Q, Walker DM, McDonald JD, . 2007. Age-, gender-, and species-dependent mutagenicity in T cells of mice and rats exposed by inhalation to 1,3-butadiene. Chem Biol Interact 166(1–3):121–131.16945358
Meng Q, Walker DM, Scott BR, . 2004. Characterization of Hprt mutations in cDNA and genomic DNA of T-cell mutants from control and 1,3-butadiene-exposed male B6C3F1 mice and F344 rats. Environ Mol Mutagen 43(2):75–92.14991748
Miller LM. 1978. Investigation of selected potential environmental contaminants: Butadiene and its oligomers. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances. EPA560278008. PB291684.
Morrissey RE, Schwetz BA, Hackett PL, . 1990. Overview of reproductive and developmental toxicity studies of 1,3-butadiene in rodents. Environ Health Perspect 86:79–84.2205495
Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokinet 5(6):485–527.7002417
NAS/NRC. 1989. Report of the oversight committee. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press. Biologic markers in reproductive toxicology.
Nazaroff WW, Singer BC. 2004. Inhalation of hazardous air pollutants from environmental tobacco smoke in U.S. residences. J Expo Anal Environ Epidemiol 14(Suppl 1):S71–S77.15118748
Nieusma JL, Claffey DJ, Maniglier-Poulet C, . 1997. Stereochemical aspects of 1,3-butadiene metabolism and toxicity in rat and mouse liver microsomes and freshly isolated rat hepatocytes. Chem Res Toxicol 10:450–456.9114983
Neligan RE. 1962. Hydrocarbons in the Los Angeles atmosphere. Arch Environ Health 5:581–591.13938007
NIOSH. 1989. National Occupational Exposure Survey (NOES). Cincinnati, OH: U.S. Department of Health and Human Services CfDC, National Institute for Occupational Safety and Health.
NIOSH. 1994. NIOSH Manual of analytical methods. 1,3-Butadiene. Method 1024. http://www.cdc.gov/NIOSH/nmam/pdfs/1024.pdf. June 1, 2009.
NIOSH. 2005. 1,3-Butadiene. In: NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention, http://www.cdc.gov/niosh/npg/. May 19, 2009.
Norppa H, Sorsa M, Vainio H. 1980. Chromosomal aberrations in bone marrow of Chinese hamsters exposed to styrene and ethanol. Toxicol Lett 5:241–244.7466852
NRC. 1993. Pesticides in the diets of infants and children. Washington, DC: National Research Council. National Academy Press.
NTP. 1984. NTP toxicology and carcinogenesis studies of 1,3-butadiene (CAS No. 106-99-0) in B6C3F_1_ mice (inhalation studies). Research Triangle Park, NC: National Toxicology Program.
NTP. 1993. NTP technical report on the toxicology and carcinogenesis studies of 1,3-butadiene (CAS No. 106-99-0) in B6C3F_1_ mice (inhalation studies). Research Triangle Park, NC: National Toxicology Program. NTP TR 434.
NTP. 2005. 1,3-Butadiene. In: Report on carcinogens. 11th ed. Research Triangle Park, NC: National Toxicology Program, http://ntp-server.niehs.nih.gov/ntp/roc/eleventh/profiles/s025buta.pdf. May 19, 2009.
NTP. 2011. 1,3-Butadiene. In: Report on carcinogens. 12^th^ edition. U.S. Department of Health and Human Services, National Toxicology Program.
Oguz O, Karman D, Tuncel G. 2003. Measurement of traffic related toxic air pollutants in an urban atmosphere. Water Air Soil Pollut Focus. 3:175–192.
O’Neil MJ, Heckelman PE, Koch CB, . 2006. 1,3-Butadiene. In: O’Neil MJ, Heckelman PE, Koch CB, ., eds. Merck index. 14th ed. Whitehouse Station, NY: Merck & Co, Inc., 248.
OSHA. 2009a. 1,3-Butadiene. Occupational Safety & Health Administration. http://www.osha.gov/dts/sltc/methods/organic/org056/org056.html. June 2, 2009.
OSHA. 2009b. Toxic and Hazardous Substances. Occupational safety and health standards. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1051. http://www.osha.gov/comp-links.html. May 29, 2009.
Osterman-Golkar S, Peltonen K, Anttinen-Klemetti T, . 1996. Haemoglobin adducts as biomarkers of occupational exposure to 1,3-butadiene. Mutagenesis 11(2):145–149.8671730
Owen GM, Brozek J. 1966. Influence of age, sex and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 222–238.
Owen PE, Glaister JR. 1990. Inhalation toxicity and carcinogenicity of 1,3-butadiene in Sprague-Dawley rats. Environ Health Perspect 86:19–25.2401255
Owen PE, Glaister JR, Gaunt IF, . 1987. Inhalation toxicity studies with 1,3-butadiene 3 two year toxicity/carcinogenicity study in rats. Am Ind Hyg Assoc J 48(5):407–413.3591659
*Pacchierotti F, Tiveron C, Ranaldi R, . 1998. Reproductive toxicity of 1,3-butadiene in the mouse: Cytogenetic analysis of chromosome aberrations in first-cleavage embryos and flow cytometric evaluation of spermatogonial cell killing. Mutat Res 397(1):55–66.9463552
Pankow JF, Luo W, Tavakoli AD, . 2004. Delivery levels and behavior of 1,3-butadiene, acrylonitrile, benzene, and other toxic volatile organic compounds in mainstream tobacco smoke from two brands of commercial cigarettes. Chem Res Toxicol 17(6):805–813.15206901
Pankow JF, Watanabe KH, Toccalino PL, . 2007. Calculated cancer risks for conventional and “potentially reduced exposure product” cigarettes. Cancer Epidemiol Biomarkers Prev 16(3):584–592.17372256
Patel RN, Hou CT, Laskin AI, . 1979. Microbial oxidation of gaseous hydrocarbons. II. Hydroxylation of alkanes and epoxidation of alkenes by cell-free particulate fractions of methane-utilizing bacteria. J Bacteriol 139:675–679.222739
Patel RN, Hou CT, Laskin AI. 1982a. Oxidation of gaseous hydrocarbons and related compounds by methanotrophic organisms. In: Developments in industrial microbiology, Vol. 23, 187–205.
Patel RN, Hou CT, Laskin AI, . 1982b. Microbial oxidation of hydrocarbons: Properties of a soluble methane monoxygenase from a facultative methane utilizing organism Methlobacterium sp. strain CRL-26. Appl Environ Microbiol 44(5):1130–1137.16346133
Pellizzari ED, Michael LC, Thomas KW, . 1995. Identification of 1,3-butadiene, benzene, and other volatile organics from wok oil emissions. J Expo Anal Environ Epidemiol 5(1):77–87.7663151
Penn A, Snyder CA. 2007. 1,3-Butadiene exposure and cardiovascular disease. Mutat Res 621(1–2):42–49.17420031
Perbellini L, Princivalle A, Carpelloni M, . 2003. Comparison of breath, blood and urine concentrations in the biomonitoring of environmental exposure to 1,3-butadiene, 2,5-dimethylfuran, and benzene. Int Arch Occup Environ Health 76(6):461–466.12687377
Péry ARR, Bois FY. 2009. Stochasticity in physiologically based kinetics models: Implications for cancer risk assessment. Risk Anal 29(8):1182–1191.19508449
Pohlova H, Rossner P, Sram RJ. 1985. Cytogenetic analysis of human peripheral blood lymphocytes in culture exposed in vitro to styrene and styrene oxide. J Hyg Epidemiol Microbiol Immunol 29:269–274.
Preston RJ. 2007. Cancer risk assessment for 1,3-butadiene: Data integration opportunities. Chem Biol Interact 166(1–3):150–155.16647696
Recio L, Osterman-Golkar S, Csanady GA, . 1992. Determination of mutagenicity in tissues of transgenic mice following exposure to 1,3-butadiene and N-ethyl-N-nitrosourea. Toxicol Appl Pharmacol 117(1):58–64.1440614
Reiss R. 2006. Temporal trends and weekend-weekday differences for benzene and 1,3-butadiene in Houston, Texas. Atmos Environ 40(25):4711–4724.
Reiss R, Griffin J. 2004. Exploratory data analysis of benzene and 1,3-butadiene measurements for air toxics risk assessment in Houston. Alpharetta, GA: Coordinating Research Council.
Reynolds P, Von Behren J, Gunier RB, . 2003. Childhood cancer incidence rates and hazardous air pollutants in California: An exploratory analysis. Environ Health Perspect 111(4):663–668.12676632
Santos-Burgoa C, Matanoski GM, Zeger S, . 1992. Lymphohematopoietic cancer in styrene-butadiene polymerization workers. Am J Epidemiol 136(7):843–854.1442750
Sapkota A, Buckley TJ. 2003. The mobile source effect on curbside 1,3-butadiene, benzene, and particle-bound polycyclic aromatic hydrocarbons assessed at a tollbooth. J Air Waste Manag Assoc 53(6):740–748.12828334
Sapkota A, Halden RU, Dominici F, . 2006. Urinary biomarkers of 1,3-butadiene in environmental settings using liquid chromatography isotope dilution tandem mass spectrometry. Chem Biol Interact 160(1):70–79.16423335
Sasiadek M, Jarventaus H, Sorsa M. 1991. Sister-chromatid exchanges induced by 1,3-butadiene and its epoxides in CHO cells. Mutat Res 263(1):47–50.2034239
Sathiakumar N, Delzell E. 2007. A follow-up study of women in the synthetic rubber industry: Study methods. Chem Biol Interact 166:25–28.17229413
Sathiakumar N, Delzell E, Cheng H, . 2007. Validation of 1,3-butadiene exposure estimates for workers at a synthetic rubber plant. Chem Biol Interact 166(1–3):29–43.17097078
Sathiakumar N, Graff J, Macaluso M, . 2005. An updated study of mortality among North American synthetic rubber industry workers. Occup Environ Med 62:822–829.16299089
Sax Sl, Bennett DH, Chilllrud SN, . 2004. Differences in source emission rates of volatile organic compounds in inner-city residences of New York City and Los Angeles. J Expo Anal Environ Epidemiol 14(Suppl 1):S95–S109.15118751
Schettgen T, Musiol A, Alt A, . 2009. A method for the quantification of biomarkers of exposure to acrylonitrile and 1,3-butadiene in human urine by column-switching liquid chromatography-tandem mass spectrometry. Anal Bioanal Chem 393(3):969–981.19018522
Schmidt V, Loeser E. 1985. Species differences in the formation of butadiene monoxide from 1,3-butadiene. Arch Toxicol 57:222–225.3879165
Schmidt V, Loeser E. 1986. Epoxidation of 1,3-butadiene in liver and lung tissue of mouse, rat, monkey and man. Adv Exp Med Biol 197:951–957.3766304
Sielken RL, Jr., Reitz RH, Hays SM. 1996. Using PBPK modeling and comprehensive realism methodology for the quantitative cancer risk assessment of butadiene. Toxicology 113(1–3):231–237.8901903
Sharief Y, Brown AM, Backer LC, . 1986. Sister chromatid exchange and chromosome aberration analyses in mice after in vivo exposure to acrylonitrile, styrene, or butadiene monoxide. Environ Mutagen 8:439–448.3709426
Shen S, Zhang F, Zeng S, . 2009. An approach based on liquid chromatography/electrospray ionization-mass spectrometry to detect diol metabolites as biomarkers of exposure to styrene and 1,3-butadiene. Anal Biochem 386(2):186–193.19111668
Shugaev BB. 1969. Concentrations of hydrocarbons in tissues as a measure of toxicity. Arch Environ Health 18:878–882.5770689
Sigsby JEJ, Tejada S, Ray W. 1987. Volatile organic compound emissions from 46 in-use passenger cars. Environ Sci Technol 21:466–475.22296134
Sills RC, Hong HL, Boorman GA, . 2001. Point mutations of K-ras and H-ras genes in forestomach neoplasms from control B6C3F_1_ mice and following exposure to 1,3-butadiene, isoprene or chloroprene for up to 2-years. Chem Biol Interact 135–136:373–386.
Slikker W, Andersen ME, Bogdanffy MS, . 2004. Dose-dependent transitions in mechanisms of toxicity: Case studies. Toxicol Appl Pharmacol 201:226–294.15582646
Smith TJ, Lin YS, Mezzetti M, . 2001. Genetic and dietary factors affecting human metabolism of 1,3-butadiene. Chem Biol Interact 135–136:407–428.
Sorsa M, Osterman-Golkar S, Peltonen K, . 1996. Assessment of exposure to butadiene in the process industry [Abstract]. Toxicology 113(1–3):77–83.8901885
Šrám RJ, Rossner P, Peltonen K, . 1998. Chromosomal aberrations, sister-chromatid exchanges, cells with high frequency of SCE, micronuclei and comet assay parameters in 1,3-butadiene-exposed workers. Mutat Res 419(1–3):145–154.9804932
SRI. 2008. 1,3-Butadiene. In: 2008 Directory of chemical producers. Menlo Park, CA: SRI Consulting, 457–458.
Startin JR, Gilbert J. 1984. Single ion monitoring of butadiene in plastics and foods by coupled mass spectometry — automatic head-space gas chromatography. J Chromatogr 294:427–430.6746800
Stephens ER, Burleson F. 1967. Analysis of the atmosphere for light hydrocarbons. J Air Pollut Control Assoc 17:147–153.6038461
Stephens ER, Burleson FR. 1969. Distribution of light hydrocarbons in ambient air. J Air Pollut Control Assoc 19:929–936.
Stump FD, Dropkin DL. 1985. Gas chromatographic method for quantitative determination of C_2_ to C_13_ hydrocarbons in roadway vehicle emissions. Anal Chem 57:2629–2634.
Stump FD, Tejada S, Ray W, . 1989. The influence of ambient temperature on tailpipe emissions from 1984-1987 model year light duty gasoline motor vehicles. Atmos Environ 23:307–320.
Stutz DR, Janusz SJ. 1988. Hazardous materials injuries. A handbook for pre-hospital care 2nd ed. Beltsville, MD: Bradford Communication Corporation, 296–297.
Sun HN, Wristers JP. 2002. Butadiene. In: Kirk-Othmer encyclopedia of chemical technology. New York, NY: John Wiley & Sons, 365–392. http://mrw.interscience.wiley.com/emrw/9780471238966/kirk/article/butasun.a01/current/pdf. June 2, 2009.
Sun JD, Dahl AR, Bond JA, . 1989a. Metabolism of inhaled butadience to monkeys: Comparison to rodents. Exp Pathol 37:133–135.2637143
Sun JD, Dahl AR, Bond JA, . 1989b. Characterization of hemoglobin adduct formation in mice and rats after administration of [[struck: ^14^]C]butadiene or [^14^C]isoprene. Toxicol Appl Pharmacol 100:86–95.2763304
Swain CM, Booth ED, Watson WP. 2003. Metabolic distribution of radioactivity in Sprague-Dawley rats and B6C3F_1_ mice exposed to 1,3-[2,3-14^C^]-butadiene by whole body exposure. Chem Biol Interact 145:175–189.12686494
Sweeney LM, Himmelstein MW, Gargas ML. 2001. Development of a preliminary physiologically based toxicokinetic (PBTK) model for 1,3-butadiene risk assessment. Chem Biol Interact 135–136:303–322.
Sweeney LM, Himmelstein MW, Schlosser PM, . 1996. Physiologically based pharmacokinetic modeling of blood and tissue epoxide measurements for butadiene. Toxicology 113(1–3):318–321.8901917
Sweeney LM, Schlosser PM, Medinsky Ma, . 1997. Physiologically based pharmacokinetic modeling of 1,3-butadiene, 1,2-epoxy-3-butene, and 1,2:3,4-diepoxybutane toxicokinetics in mice and rats. Carcinogenesis 18(4):611–625.9111190
Swenberg JA, Bordeerat NK, Boysen G, . 2011. 1,3-Butadiene: Biomarkers and application to risk assessment. Chem Biol Interact 192(1–2):150–154.20974116
Swenberg JA, Boysen G, Georgieva N, . 2007. Future directions in butadiene risk assessment and the role of cross-species internal dosimetry. Chem Biol Interact 166(1–3):78–83.17343837
Tates AD, van Dam FJ, de Zwart FA, . 1996. Biological effect monitoring in industrial workers from the Czech Republic exposed to low levels of butadiene [Abstract]. Toxicology 113(1–3):91–99.8901887
Texas Air Control Board. 1990. Written communication to Bill Henriques, Agency for Toxic Substances and Disease Registry, regarding 1,3-butadiene concentrations in air. Texas Air Control Board, Austin, TX.
Thomas K, Colborn T. 1992. Organochlorine endocrine disruptors in human tissue. In: Colborn T, Clement C, eds. Chemically induced alterations in sexual and functional development: The wildlife/human connection. Princeton, NJ: Princeton Scientific Publishing, 365–394.
Thornton-Manning JR, Dahl AR, Bechtold WE, . 1995a. Disposition of butadiene monoepoxide and butadiene diepoxide in various tissues of rats and mice following a low-level inhalation exposure to 1,3-butadiene. Carcinogenesis 16(8):1723–1731.7634396
Thornton-Manning JR, Dahl AR, Bechtold WE, . 1995b. Gender differences in the metabolism of 1,3-butadiene in Sprague-Dawley rats following a low level inhalation exposure. Carcinogenesis 16(11):2875–2878.7586213
Thornton-Manning JR, Dahl AR, Bechtold WE, . 1997. Comparison of the disposition of butadiene epoxides in Sprague-Dawley rats and B6C3F_1_ mice following a single and repeated exposures to 1,3-butadiene via inhalation. Toxicology 123(1–2):125–134.9347927
Thurmond LM, Lauer LD, House RV, . 1986. Effect of short-term inhalation exposure to 1,3-butadiene on murine immune functions. Toxicol Appl Pharmacol 86(2):170–179.3787617
Thweatt WD, Harward CN, Sr., Parrish ME. 2007. Measurement of acrolein and 1,3-butadiene in a single puff of cigarette smoke using lead-salt tunable diode laser infrared spectroscopy. Spectrochim Acta A Mol Biomol Spectrosc 67(1):16–24.17141561
Tice RR. 1988. The cytogenetic evaluation of in vivo genotoxic and cytotoxic activity using rodent somatic cells. Cell Biol Toxicol 4(4):475–486.3228715
Tice RR, Boucher R, Luke CA, . 1987. Comparative cytogenic analysis of bone marrow damage induced in male B6C3F_1_ mice by multiple exposures to gaseous 1,3-butadiene. Environ Mutagen 9:235–250.3569168
Tommasi AM, de Conti S, Dobrzynska MM, . 1998. Evaluation and characterization of micronuclei in early spermatids of mice exposed to 1,3-butadiene. Mutat Res 397(1):45–54.9463551
TRI09. 2011. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Office of Information Analysis and Access. Office of Environmental Information. U.S. Environmental Protection Agency. Toxics Release Inventory. http://www.epa.gov/triexplorer/. September 28, 2011.
Tsai SP, Ahmed FS, Ransdell JD, . 2005. A hematology surveillance study of petrochemical workers exposed to 1,3 butadiene. J Occup Environ Hyg 2(10):508–515.16147472
Tsai SP, Wendt JK, Ransdell JD. 2001. A mortality, morbidity, and hematology study of petrochemical employees potentially exposed to 1,3-butadiene monomer. Chem Biol Interact 135–136:555–567.
Uusküla M, Järventaus H, Hirvonen A, . 1995. Influence of GSTM1 genotype of sister chromatid exchange induction by styrene-7,8-oxide and 1,2-epoxy-3-butene in cultured human lymphocytes. Carcinogenesis 16(4):947–950.7728978
Vainiotalo S, Vaananen V, Vaaranrinta R. 2008. Measurement of 16 volatile organic compounds in restaurant air contaminated with environmental tobacco smoke. Environ Res 108(3):280–288.18801480
VanGinkel CG, Welten HGJ, Debont JAM. 1987. Oxidation of gaseous and volatile hydrocarbons by selected alkene-utilizing bacteria. Appl Environ Microbiol 53:2903–2907.16347505
Victorin K, Stahlberg M. 1988. A method for studying the mutagenicity of some gaseous compounds in Salmonella tymphimurium. Environ Mol Mutagen 11(1):65–77.3276508
Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238(2):476–483.8681961
Vodicka P, Stetina R, Smerak P, . 2006. Micronuclei, DNA single-strand breaks and DNA-repair activity in mice exposed to 1,3-butadiene by inhalation. Mutat Res 608(1):49–57.16807075
Ward EM, Fajen JM, Ruder AM, . 1995. Mortality study of workers in 1,3-butadiene production units identified from a chemical workers cohort. Environ Health Perspect 103(6):598–603 7556014
Ward JB, Ammenheuser MM, Bechtold WE, . 1994. hprt Mutant lymphocyte frequencies in workers at a 1,3-butadiene production plant. Environ Health Perspect 102(Suppl 9):79–85.
Ward JB, Ammenheuser MM, Whorton EB, . 1996. Biological monitoring for mutagenic effects of occupational exposure to butadiene. Toxicology 110:1–7.8658550
Ward JB, Abdel-Rahman SZ, Henderson RF, . 2001. Assessment of butadiene exposure in synthetic rubber manufacturing workers in Texas using frequencies of hprt mutant lymphocytes as a biomarker. Chem Biol Interact 135–136:465–483.
Watabe T, Isobe M, Sawahata T, . 1978. Metabolism and mutagenicity of styrene. Scand J Work Environ Health 4(Suppl 2):142–155.32616
Watkinson RJ, Somerville HJ. 1976. The microbial utilization of butadiene. In: Sharpley JM, Kaplan AM, eds., Proceedings of the Third International Biodegradation Symposium London: Applied Science Publishers, 35–42.
West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
Whitworth KW, Symanski E, Coker AL. 2008. Childhood lymphohematopoietic cancer incidence and hazardous air pollutants in Southeast Texas, 1995-2004. Environ Health Perspect 116:1576–1580.19057714
WHO. 2000. Air quality guidelines. 2nd edition. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/air/activities/20050223_4. May 11, 2009.
WHO. 2006. Guidelines for drinking-water quality. 3rd edition. Geneva, Switzerland: World Health Organization. http://www.who.int/water_sanitation_health/dwq/gdwq3/en/. May 11, 2009.
Wickliffe JK, Ammenheuser MM, Adler PJ, . 2009. Evaluation of frequencies of HPRT mutant lymphocytes in butadiene polymer workers in a southeast Texas facility. Environ Mol Mutagen 50(2):82–87.19107895
Widdowson EM, Dickerson JWT. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advance treatise. Volume II: The elements Part A. New York, NY: Academic Press, 1–247.
Wilson RH. 1944. Health hazards encountered in the manufacture of synthetic rubber. J Am Med Assoc 124(11):701–703.
Xiao Y, Tates AD. 1995. Clastogenic effects of 1,3-butadiene and its metabolites 1,2-epoxybutene and 1,2,3,4-diepoxybutane in splenocytes and germ cells of rats and mice in vivo. Environ Mol Mutagen 26(2):97–108.7556116
Zhao C, Vodicka P, Sram RJ, . 2000. Human DNA adducts of 1,3-butadiene, an important environmental carcinogen. Carcinogenesis 21(1):107–111.10607741
Zhao C, Vodicka P, Sram RJ, . 2001. DNA adducts of 1,3-butadiene in humans: Relationships to exposure, GST genotypes, single-strand breaks, and cytogenetic end points. Environ Mol Mutagen 37(3):226–230.11317340
Zhou XT, Li LR, Cui MY, . 1986. Cytogenetic monitoring of petrochemical workers [Abstract]. Mutat Res 175(4):237–242.3785277
Zhuang SM, Cochran C, Goodrow T, . 1997. Genetic alterations of p53 and ras genes in 1,3-butadiene- and 2’,3’-dideoxycytidine-induced lymphomas. Cancer Res 57(13):2710–2714.9205081
Zhuang SM, Wiseman RW, Soderkvist P. 2002. Frequent mutations of the Trp53, Hras1 and β-catenin (Catnb) genes in 1,3-butadiene-induced mammary adenocarcinomas in B6C3F_1_ mice. Oncogene 21(36):5643–5648.12165863
Ziegler EE, Edwards BB, Jensen RL, . 1978. Absorption and retention of lead by infants. Pediatr Res 12(1):29–34.643372