# 8 REGULATIONS, ADVISORIES, AND GUIDELINES

EPA (IRIS 2012) has established an inhalation reference concentration (RfC) for 1,3-butadiene of 0.9 ppb based on a BMCL_10_ of 0.88 ppm for ovarian atrophy in female B6C3F1 mice exposed to 1,3-butadiene by inhalation for 6 hours/day, 5 days/week for up to 103 weeks.

EPA has not established an oral reference dose (RfD) for 1,3-butadiene (IRIS 2012).

OSHA has required employers of workers who are occupationally exposed to 1,3-butadiene to institute engineering controls and work practices to reduce and maintain employee exposure at or below permissible exposure limits (PELs) (OSHA 2009b). The employer must use engineering and work practice controls to reduce exposures to not exceed 1 ppm for 1,3-butadiene at any time (OSHA 2009b).

EPA has designated 1,3-butadiene as a hazardous air pollutant (HAP) under the Clean Air Act (CAA) (EPA 2009b). 1,3-Butadiene is on the list of chemicals appearing in “Toxic Chemicals Subject to Section 313 of the Emergency Planning and Community Right-to-Know Act of 1986” and has been assigned a reportable quantity (RQ) limit of 100 pounds (EPA 2009d). The RQ represents the amount of a designated hazardous substance which, when released to the environment, must be reported to the appropriate authority.

The international and national regulations, advisories, and guidelines regarding 1,3-butadiene in air, water, and other media are summarized in Table 8-1.

Table 8-1 Regulations, Advisories, and Guidelines Applicable to 1,3-Butadiene

Agency | | Description | Information | Reference
[underlined: INTERNATIONAL]
Guidelines:
| IARC | Carcinogenicity classification | Group 1^a^ | IARC 2009
| WHO | Air quality guidelines | No guideline value is recommended at this time | WHO 2000
| | Drinking water quality guidelines | No | WHO 2006
[underlined: NATIONAL]
Regulations and Guidelines:
a. | Air
| ACGIH AIHA | TLV (8-hour TWA) | 2 ppm | ACGIH 2008
| AIHA | ERPG-1^b^ | 10 ppm | AIHA 2008
| | ERPG-2^b^ | 200 ppm
| | ERPG-3^b^ | 5,000 ppm
| EPA | RfC | 0.9 ppb | IRIS 2012
| | Inhalation unit risk | 3×10^−5^ per μg/m^3^
| EPA | AEGL-1^c^ | | EPA 2009a
| | 10 minutes | 670 ppm
| | 30 minutes | 670 ppm
| | 60 minutes | 670 ppm
| | 4 hours | 670 ppm
| | 8 hours | 670 ppm
| | AEGL-2^c^
| | 10 minutes | 6,700 ppm
| | 30 minutes | 6,700 ppm
| | 60 minutes | 5,300 ppm
| | 4 hours | 3,400 ppm
| | 8 hours | 2,700 ppm
| | AEGL-3^c^
| | 10 minutes | 27,000 ppm
| | 30 minutes | 27,000 ppm
| | 60 minutes | 22,000 ppm
| | 4 hours | 14,000 ppm
| | 8 hours | 6,800 ppm
| | Level of distinct odor awareness | 3.7 ppm
| | Hazardous air pollutant | Yes | EPA 2009b; 42 USC 7412
| | Regulated flammable substances and threshold quantities for accidental release prevention^d^ | 10,000 pounds | EPA 2009c; 40 CFR 68.130
| NIOSH | REL (10-hour TWA) | Potential occupational carcinogens | NIOSH 2005
| | IDLH (10% LEL) | 2,000 ppm
| | Target organs | Eyes, respiratory system, central nervous system, and reproductive system
| OSHA | PEL (8-hour TWA) for general industry | 1 ppm | OSHA 2009b; 29 CFR 1910.1051
| | STEL (15-minutes) | 5 ppm | OSHA 2009b; 29 CFR 1910.1051
b. | Water
| EPA | Drinking water standards and health advisories | No | EPA 2006a
| | National primary drinking water standards | No | EPA 2003b
| | National recommended water quality criteria | No | EPA 2006b
c. | Food
| FDA | EAFUS^e^ | No | FDA 2008
d. | Other
| ACGIH | Carcinogenicity classification | A2^f^ | ACGIH 2008
| EPA | Carcinogenicity classification | Carcinogenic to humans by inhalation | IRIS 2012
| | RfD | No data
| | Superfund, emergency planning, and community right-to-know
| | Designated CERCLA hazardous substance | Yes^g^ | EPA 2009d; 40 CFR 302.4
| | Reportable quantity | 100 pounds
| | Effective date of toxic chemical release reporting | 01/01/1987 | EPA 2009e; 40 CFR 372.65
| NTP | Carcinogenicity classification | Known to be a human carcinogen | NTP 2005

a Group 1: carcinogenic to humans

b ERPG-1 is the maximum airborne concentration below which nearly all individuals could be exposed for up to 1 hour without experiencing other than mild, transient health effects; ERPG-2 is the maximum airborne concentration below which nearly all individuals could be exposed for up to 1 hour without experiencing irreversible or other serious adverse effects; and ERPG-3 is the maximum airborne concentration below which nearly all individuals could be exposed for up to 1 hour without life-threatening health effects (AIHA 2008).

c AEGL-1 is the airborne concentration of a substance above which it is predicted that the general population, including susceptible individuals, could experience notable discomfort, irritation, or certain asymptomatic nonsensory effects, however, the effects are not disabling and are transient and reversible upon cessation of exposure; AEGL-2 is the airborne concentration of a substance above which it is predicted that the general population, including susceptible individuals, could experience irreversible or other serious, long-lasting adverse health effects or an impaired ability to escape; and AEGL-3 is the airborne concentration of a substance above which it is predicted that the general population, including susceptible individuals, could experience life-threatening health effects or death (EPA 2009a).

d Basis for listing: flammable gas

e The EAFUS list of substances contains ingredients added directly to food that FDA has either approved as food additives or listed or affirmed as GRAS.

f A2: suspected human carcinogen

g Designated CERCLA hazardous substance pursuant to Section 112 of the Clean Air Act

ACGIH = American Conference of Governmental Industrial Hygienists; AEGL = acute exposure guideline levels; AIHA = American Industrial Hygiene Association; CERCLA = Comprehensive Environmental Response, Compensation, and Liability Act; CFR = Code of Federal Regulations; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; ERPG = emergency response planning guidelines; FDA = Food and Drug Administration; GRAS = Generally Recognized As Safe; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; LEL = lower explosive limit; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; STEL = short-term exposure limit; TLV = threshold limit values; TWA = time-weighted average; USC = United States Code; WHO = World Health Organization