# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Information regarding the chemical identity of 1,3-butadiene is located in Table 4-1. This information includes synonyms, chemical formula and structure, and identification numbers.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of 1,3-butadiene is located in Table 4-2.

Table 4-1 Chemical Identity of 1,3-Butadiene^a^

Characteristic | Information
Chemical name | 1,3-Butadiene
Synonyms and trade names | Butadiene; buta-1,3-diene; biethylene; bivinyl; divinyl; vinylethylene; erythrene; alpha,-gamma-butadiene; pyrrolylene^b^
Chemical formula | C_4_H_6_
Chemical structure | [image]
Identification numbers:
CAS registry | 106-99-0
NIOSH RTECS | EI9275000^c^
EPA hazardous waste | R0377-0754^d^
DOT/UN/NA/IMDG shipping | 1010
EINECS | 203-450-8
HSDB | 181
NCI | C50602

a All information obtained from HSDB 2009 and ChemID Plus Advanced 2009 except where noted.

b O’Neil et al. 2006.

c NIOSH 2005.

d Miller 1978.

CAS = Chemical Abstracts Service; DOT/UN/NA/IMDG = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EINECS = European Inventory of Existing Commercial chemical Substances; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of 1,3-Butadiene

Property | 1,3-Butadiene | Reference
Molecular weight | 54.09 | O’Neil et al. 2006
Color | Colorless | Lewis 2007
Physical state | Gas | Lewis 2007
Melting point | −108.966 °C | O’Neil et al. 2006
Boiling point | −4.5 °C | O’Neil et al. 2006
Density:
at 25 °C (g/cm^3^) | 0.6149 | Lide 2008
Vapor density | 1.88 (air=1) | NIOSH 2005
Odor | Mildly aromatic; gasoline-like | Lewis 2007
Water | Not applicable^a^ | Amoore and Hautala 1983
Air | 1.6 ppm | Amoore and Hautala 1983
Odor threshold
Solubility:
Water at 25 °C | 735 mg/L | McAuliffe 1966
Organic solvent(s) | Soluble in ether, ethanol and benzene; very soluble in acetone | Lide 2008
Partition coefficients:
Log K_ow_ | 1.99 | Hansch et al. 1995
K_oc_ | 288 (estimated)^b^ | HSDB 2009
Vapor pressure at 25 °C | 2.11×10^3^ mm Hg | AIChE 2000
Henry’s law constant at 25 °C | 7.4×10^−2^ atm-m^3^/mol (estimated)^c^ | HSDB 2009
Autoignition temperature | 414 °C | Lewis 2007
Flashpoint | −76 °C | Lewis 2007
Explosive limits | 2.0-11.5% | O’Neil et al. 2006
Conversion factors | 1 ppm=2.21 mg/m^3^; 1 mg/m^3^=0.452 ppm | NIOSH 2005

a Amoore and Hautala (1983) reported an odor threshold of 0.0014 ppm for 1,3-butadiene in water; however, these authors state that this solution lacks enough persistence for this value to be used for reference purposes.

b This K_oc_ value was estimated using the measured log K_ow_ value (1.99) and a regression derived equation.

c This Henry’s Law constant value was calculated from the measured vapor pressure (2.11×10^3^ mm Hg at 25 °C) and water solubility (735 mg/L).