# PEER REVIEW

A peer review panel was assembled for lead. The panel consisted of the following members:

1. Philip Landrigan, M.D., Ethel H. Wise, Professor of Community and Preventive Medicine and Professor of Pediatrics, Director, Division of Environmental and Occupational Medicine, Mount Sinai School of Medicine, New York, New York;
2. Deborah Cory-Slechta, Ph.D., Director, Environmental and Occupational Health Sciences Institute, Chair, Department of Environmental and Occupational Medicine, Robert Wood Johnson Medical University of Medicine and Dentistry of New Jersey, Piscataway, New Jersey; and
3. Howard Hu, M.D., M.P.H., Professor of Occupational and Environmental Medicine, Harvard School of Public Health, Boston, Massachusetts.

These experts collectively have knowledge of lead's physical and chemical properties, toxicokinetics, key health end points, mechanisms of action, human and animal exposure, and quantification of risk to humans. All reviewers were selected in conformity with the conditions for peer review specified in Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

Scientists from the Agency for Toxic Substances and Disease Registry (ATSDR) have reviewed the peer reviewers' comments and determined which comments will be included in the profile. A listing of the peer reviewers' comments not incorporated in the profile, with a brief explanation of the rationale for their exclusion, exists as part of the administrative record for this compound.

The citation of the peer review panel should not be understood to imply its approval of the profile's final content. The responsibility for the content of this profile lies with the ATSDR.