# CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Lead is a naturally occurring element and is a member of Group 14 (IVA) of the periodic table. Natural lead is a mixture of four stable isotopes, ^208^Pb (51–53%), ^206^Pb (23.5– −27%), ^207^Pb (20.5–23%), and ^204^Pb (1.35–1.5%). Lead isotopes are the stable decay product of three naturally radioactive elements: ^206^Pb from uranium, ^207^Pb from actinium, and ^208^Pb from thorium.

Lead is not a particularly abundant element, but its ore deposits are readily accessible and widely distributed throughout the world. Its properties, such as corrosion resistance, density, and low melting point, make it a familiar metal in pipes, solder, weights, and storage batteries. The chemical identities of lead and several of its compounds are given in Table 4-1.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Lead exists in three oxidation states: Pb(0), the metal; Pb(II); and Pb(IV). In the environment, lead primarily exists as Pb(II). Pb(IV) is only formed under extremely oxidizing conditions and inorganic Pb(IV) compounds are not found under ordinary environmental conditions. While organolead(II) compounds are known, organolead chemistry is dominated by the tetravalent (+4) oxidation state. Metallic lead, Pb(0) exists in nature, but its occurrence is rare.

Lead’s extensive use is largely due to its low melting point and excellent corrosion resistance in the environment. When exposed to air and water, films of lead sulfate, lead oxides, and lead carbonates are formed; these films act as a protective barrier that slows or halts corrosion of the underlying metal. Lead is amphoteric, forming plumbous and plumbic salts in acid and plumbites and plumbates in alkali. Lead is positioned slightly above hydrogen in the electromotive series and therefore should theoretically replace hydrogen in acids. However, the potential difference is small and the high hydrogen overvoltage prevents replacement (King and Ramachandran 1995; Sutherland and Milner 1990).

Data on the physical and chemical properties of lead and several of its compounds are given in Table 4-2

Table 4-1 Chemical Identity of Lead and Compounds

Characteristic | Lead^a^ | Lead acetate^a^ | Lead azide^b^ | Lead bromide^c^
Synonyms | Lead metal; plumbum; pigment metal | Lead(2+) acetic acid; plumbous acetate | Lead (2+) azide; Lead diazinde | Lead (II) bromide^d^
Trade name | CI77575 | Salt of Saturn; sugar of lead; Unichem PBA | RD 1333 | No data
Chemical formula | Pb | C_4_H_6_O_4_Pb | N_6_Pb | Br_2_Pb
Chemical structure^e^ | Pb | | Pb(N_3_)_2_ | PbBr_2_
Identification numbers:
CAS registry | 7439-92-1 | 301-04-2 | 13424-46-9 | 10031-22-8
NIOSH RTECS | OF7525000^b^ | AI5250000^b^ | OF8650000 | No data
EPA hazardous waste | D008 | U144, D008 | No data | No data
OHM/TADS | 7216776 | 7217255 | No data | No data
DOT/UN/NA/IMCO shipping | NA | UN 1616, IMO 6.1 | UN 0129 | No data
HSDB | 231 | 1404 | No data | No data
NCI | No data | No data | No data | No data

Characteristic | Lead chloride^a^ | Lead chromate^a^ | Lead fluoroborate^a^ | Lead iodide^a^
Synonyms | Lead(2+) chloride; lead (II) chloride; plumbous chloride | Chromic acid (H_2_CrO_4_) lead(2+) salt; lead chromate (VI); Yellow 34 | Borate(1−), tetrafluoro, lead(2+); lead borofluoride; lead boron fluoride; lead tetrafluoroborate | Lead diiodide; lead(II) iodide; plumbous iodide
Trade name | No data | Canary Chrome Yellow 40–2250; Cologne Yellow; King's Yellow | No data | No data
Chemical formula | Cl_2_Pb | CrO_4_Pb | B_24_F_8_Pb | I_2_Pb
Chemical structure^e^ | PbCl_2_ | PbCrO_4_ | Pb(BF_4_)_2_ | PbI_2_
Identification numbers:
CAS registry | 7758-95-4 | 7758-97-6 | 13814-96-5 | 10101-63-0
NIOSH RTECS | OF9450000^b^ | GB2975000^b^ | ED2700000^b^ | OG1515000^b^
EPA hazardous waste | No data | D007, D008 | D008 | D008
OHM/TADS | 7217256 | No data | 7217378 | No data
DOT/UN/NA/IMCO shipping | NA 2291 | No data | NA 2291; 1MO 6.1 | NA 2811
HSDB | 6309 | 1650 | 1991 | 636
NCI | No data | No data | No data | No data

Characteristic | Lead molybdenum chromate^b^ | Lead nitrate^a^ | Lead oxide^a^
Synonyms | Chromic acid, lead and molybdenum salt; molybdenum-lead chromate; molybdenum orange; Scarlet chrome; Red 104 | Lead dinitrate; nitric acid lead(2+) salt; lead (II) nitrate; plumbous nitrate | Lead(2+) oxide; lead oxide, yellow lead monoxide; litharge; massicot
Trade name | C.I. Pigment Red 104 | No data | CI 77577; CI Pigment Yellow 46
Chemical formula | CRMoOPb | N_2_O_6_Pb | OPb
Chemical structure^e^ | No data | Pb(NO_3_)_2_ | PbO
Identification numbers:
CAS registry | 12709-98-7 | 10099-74-8 | 1317-36-8
NIOSH RTECS | OG1625000 | OG2100000^b^ | OG1750000^b^
EPA hazardous waste | No data | D008 | D008
OHM/TADS | No data | 7217257 | No data
DOT/UN/NA/IMCO shipping | No data | UN 1469, IMO 5.1 | No data
HSDB | No data | 637 | 638
NCI | No data | No data | No data

Characteristic | Lead phosphate^a^ | Lead styphnate^f^ | Lead sulfate^a^
Synonyms | Lead(2+) phosphate; phosphoric acid lead(2+) salt | 1,3-benzenediol, 2,4,6-trinitro, lead (2+) salt (1:1); resorcinol, 2,4,6-trinitro; lead (2+) salt (1:1); lead (II) styphnate | Sulfuric acid lead(2+) salt; lead (II) sulfate
Trade name | Perlex Paste 500; Perlex Paste 600A; CI 77622 | No data | CI 77630; Fast hite; Lead Bottoms; Mulhouse White
Chemical formula | O_8_P_2_Pb_3_ | C_6_H_3_N_3_O_8_·Pb | O_4_PbS
Chemical structure^e^ | Pb_3_(PO_4_)_2_ | | PbSO_4_
Identification numbers:
CAS registry | 7446-27-7 | 15245-44-0 | 7446-14-2
NIOSH RTECS | OG3675000^b^ | No data | OG4375000^b^
EPA hazardous waste | D008, U145 | No data | No data
OHM/TADS | No data | No data | No data
DOT/UN/NA/IMCO shipping | No data | No data | UN 1794; NA 1794; IMO 8.0
HSDB | 2637 | No data | 6308
NCI | No data | No data | No data

Characteristic | Lead sulfide^a^ | Tetraethyl lead^a^ | Lead carbonate^a^
Synonyms | Lead monosulfide; lead(2+) sulfide; Lead (II) sulfide; plumbous sulfide; natural galena | Lead, tetraethyl; TEL; tetraethyllead; tetraethyl-plumbane | Carbonic acid lead salt; cerussite
Trade name | No data | No data | No data
Chemical formula | PbS | C_8_H_20_Pb | PbCO_3_
Chemical structure^e^ | PbS | | PbCO_3_
Identification numbers:
CAS registry | 1314-87-0 | 78-00-2 | 598-63-0
NIOSH RTECS | OG4550000 | TP4550000 | OF9275000
EPA hazardous waste | D008 | P110; D008 | D008
OHM/TADS | 7800071 | 7216922 | No data
DOT/UN/NA/IMCO shipping | NA 2291; IMO 6.1 | NA 1649; IMO 6.1 | No data
HSDB | 639 | 841 | 1649
NCI | No data | C54988 | No data

a HSDB 2007

b RTECS 2007

c Lewis 1993

d Lenga 1988

e ChemIDplus 2005

f EPA 2006

CAS = Chemical Abstracts Services; DOT/UN/NA/IMO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of Lead and Compounds

Property | Lead^a^ | Lead acetate^a^ | Lead azide^b^ | Lead bromide^b^
Molecular weight | 207.2 | 325.28 | 291.25 | 367.04
Color | Bluish-gray | White | White | White
Physical state | Solid | Solid | Needles or powder | Crystalline powder
Melting point | 327.4 °C | 280 °C | No data | 373 °C
Boiling point | 1,740 °C | Decomposes above 200 °C | Explodes at 350 °C | 916 °C
Density at 20 °C | 11.34 g/cm^3^ | 3.25 g/cm^3^ | No data | 6.66 g/cm^3^d
Odor | None | Slightly acetic | No data | No data
Odor threshold:
Water | No data | No data | No data | No data
Air | No data | No data | No data | No data
Solubility:
Water at 25 °C | Insoluble | 443,000 mg/L at 520 °C | 230 mg/L at 18 °C | 8,441 mg/L at 20 °C
Nitric acid | Soluble | No data | No data | No data
Hot conc. sulfuric acid | Soluble | No data | No data | No data
Organic solvents | Insoluble | Soluble in glycerol, very slight in alcohol | Acetic acid^c^ | Insoluble in alcohol
Partition coefficients:
Log K_ow_ | No data | No data | No data | No data
Log K_oc_ | No data | No data | No data | No data
Vapor pressure | 1.77 mmHg at 1,000 °C | No data | No data | 1 mm Hg at 513 °C
Henry’s law constant | No data | No data | No data | No data
Autoignition temperature | No data | No data | No data | No data
Flashpoint | No data | No data | No data | No data
Flammability limits | No data | No data | Not flammable | No data
Conversion factors^j^ | Not relevant^e^ | Not relevant^e^ | Not relevant^e^ | Not relevant^e^
Explosive limits | No data | Lead acetate-lead bromate double salt is explosive | No data | No data
Valence state | 0^f^ | +2 | +2 | +2

Property | Lead chloride^a^ | Lead chromate^a^ | Lead fluoroborate^b^ | Lead iodide^a^
Molecular weight | 278.11 | 323.19 | 380.81 | 461.01
Color | White | (Orange-)yellow | Colorless | Bright or golden yellow
Physical state | Solid | Solid | Crystalline powder | Hexagonal crystals; powder
Melting point | 501 °C | 844 °C | No data | 402 °C
Boiling point | 950 °C | Decomposes^c^ | No data | Decomposes at 872 °C
Density at 20 °C | 5.85 g/cm^3^ | 6.12 g/cm^3^ at 15 °C | 1.75 g/cm^3^ | 6.16 g/cm^3^
Odor | No data | Faint odor (solution) | Odorless | No data
Odor threshold | No data | No data | No data | No data
Solubility:
Water at 25 °C | 9,900 mg/L at 20 °C | 0.2 mg/L | No data | 630 mg/L at 20 °C
Nitric acid | No data | Soluble in dilute acid | No data | No data
Hot conc. sulfuric acid | No data | No data | No data | No data
Organic solvents | Insoluble in alcohol^c^ | Insoluble in acetic acid | Decomposes in alcohol^c^ | Insoluble in alcohol^b^
Partition coefficients:
Log K_ow_ | No data | No data | No data | No data
Log K_oc_ | No data | No data | No data | No data
Vapor pressure | 1 mm Hg at 547 °C | No data | No data | 1 mm Hg at 479 °C
Henry’s law constant | No data | No data | No data | No data
Autoignition temperature | No data | No data | No data | No data
Flashpoint | No data | No data | No data | No data
Flammability limits | No data | Flammable with combustible organic or other oxidizable materials | Not ignited readily | Not flammable
Conversion factors | Not relevant^e^ | Not relevant^e^ | Not relevant^e^ | Not relevant^e^
Explosive limits | No data | No data | No data | No data
Valence state | +2 | +2 | +2 | +2

Property | Lead molybdenum chromate^a^ | Lead nitrate^a^ | Lead oxide^a^
Molecular weight | 886.26^g^ | 331.21 | 223.20
Color | No data | Colorless or white | Reddish-yellow; yellow (above 489 °C)
Physical state | No data | Solid | Solid
Melting point | No data | Decomposes at 470 °C | 888 °C
Boiling point | No data | No data | Decomposes at 1,472 °C
Density at 20 °C | No data | 4.53 g/cm^3^ | 9.3 g/cm^3^ (Litharge); 8.0 g/cm^3^ (Massicot)^d^
Odor | No data | Odorless | No data
Odor threshold: | No data | No data | No data
Solubility:
Water at 25 °C | No data | 376,500 mg/L at 0 °C 565,000 mg/L at 20 °C | 17 mg/L at 20 °C
Nitric acid | No data | Insoluble | Soluble (Litharge)
Hot conc. sulfuric acid | No data | No data | No data
Organic solvents | No data | 1 g in 2,500 mL absolute alcohol; 1 g in 75 mL absolute alcohol | Soluble in alkali chlorides; soluble in alkali (Massicot); insoluble in alcohol
Partition coefficients:
Log K_ow_ | No data | No data | No data
Log K_oc_ | No data | No data | No data
Vapor pressure | No data | No data | No data
Henry’s law constant | No data | No data | No data
Autoignition temperature | No data | No data | No data
Flashpoint | No data | No data | No data
Flammability limits | No data | Fire risk with organics | Not readily ignited
Conversion factors | Not relevant^e^ | Not relevant^e^ | Not relevant^e^
Explosive limits | No data | Explosive with easily oxidizable substances, and lead nitrate-lead hypophosphite double salt | 2–3 drops 90% peroxyformic acid causes violent explosion
Valence state | +2 | +2 | +2

Property | Lead phosphate^a^ | Lead styphnate^h^ | Lead sulfate^a^
Molecular weight | 811.54 | 450.29^g^ | 303.26
Color | White | Orange-yellow monohydrate) | White
Physical state | Solid | Monoclinic crystals | Solid
Melting point | 1,014 °C | No data | 1,170 °C
Boiling point | No data | No data | No data
Density at 20 °C | 6.9–7.3 g/cm^3^d | No data | 6.2 g/cm^3^c
Odor | No data | No data | No data
Odor threshold: | No data | No data | No data
Solubility:
Water at 25 °C | 0.14 mg/L at 20 °C | Insoluble | 42.5 mg/L
Nitric acid | Soluble | No data | More than in water
Hot conc. sulfuric acid | No data | No data | Slightly soluble
Organic solvents | Soluble in fixed alkali hydroxides; insoluble in alcohol | No data | Insoluble in alcohol
Partition coefficients:
Log K_ow_ | No data | No data | No data
Log K_oc_ | No data | No data | No data
Vapor pressure | No data | No data | No data
Henry’s law constant | No data | No data | No data
Autoignition temperature | No data | No data | No data
Flashpoint | No data | No data | No data
Flammability limits | No data | Detonates at 260 °C | Not flammable
Conversion factors | Not relevant^e^ | Not relevant^e^ | Not relevant
Explosive limits | No data | No data | No data
Valence state | +2 | +2 | +2

Property | Lead sulfide^a^ | Tetraethyl lead^a^ | Lead carbonate^a^
Molecular weight | 239.27 | 323.45 | 267.2
Color | Black, blue, or silvery | Colorless | Colorless rhombic crystals
Physical state | Cubic or metallic crystals; powder | Oily liquid | Solid
Melting point | 1,114 °C | No data | 315 °C (decomposes)
Boiling point | Sublimes at 1,281 °C | 200 °C; 227.7 °C (with decomposition) | No data
Density at 20 °C | 7.57–7.59 g/cm^3^ | 1.653 g/cm^3^ | 6.6 g/cm
Odor | No data | No data | No data
Odor threshold: | No data | No data | No data
Solubility:
Water at 25 °C | 0.86 mg/L at 13 °C | 0.29 mg/L | 1.1 mg/L
Nitric acid | Soluble | No data | Soluble
Hot conc. sulfuric acid | Soluble (in acid) | No data | Soluble
Organic solvents | Nitric acid, hot diluted hydrochloric acid^b^; insoluble in alcohol | Benzene, ethanol, diethyl ether, gasoline petroleum ether | Insoluble in ammonia and alcohol
Partition coefficients:
Log K_ow_ | No data | 4.15 | No data
Log K_oc_ | No data | No data | No data
Vapor pressure | 10 mmHg at 975 °C | 0.26 mm Hg at 25 °C | No data
Henry’s law constant | No data | No data | No data
Autoignition temperature | No data | No data | No data
Flashpoint | No data | 93 °C (closed cup); 85 °C (open cup) | No data
Flammability limits | Noncombustible | 1.8% | Not flammable
Conversion factors | Not relevant | Not relevant | Not relevant
Explosive limits | No data | Potentially, above 80 °C | No data
Valence state | +2 | +4 | +2

a HSDB 2007

b Budavari et al. 1989

c Lide 1996

d Temperature not specified.

e Since these compounds exist in the atmosphere in the particulate state, their concentrations are expressed as µg/m^3^ only.

f Howe 1981

g Molecular weight calculated from atomic weights.

h Lewis 1993