# A FRAMEWORK TO GUIDE PUBLIC HEALTH ASSESSMENT DECISIONS AT LEAD SITES

## ABSTRACT

The Agency for Toxic Substances and Disease Registry (ATSDR) provides health consultations and assessments at hazardous waste sites. Many of these sites have potentially significant levels of lead contamination for which the Agency must assess the health implications of exposure. Typically, environmental data are used to predict blood lead (PbB) levels in order to determine at which sites, if any, follow-up action is needed. Estimating blood lead levels from environmental lead concentrations, however, can be problematic. Several approaches have been developed, including classical ingestion rate determinations and comparison to animal studies, prevalence studies extrapolated to comparable sites, regression analysis of known exposure followed by slope factor estimates of similar levels of exposure, and the Environmental Protection Agency’s (EPA) Integrated Exposure Uptake Biokinetic Model (IEUBK). Uncertainty is attendant to each of these approaches due, in part, to the limited nature of the environmental sampling data and the various site-specific factors. In this manuscript we describe an approach ATSDR developed to utilize regression analysis with multi-route uptake parameters to estimate blood lead levels.

The profound toxicity of lead has been acknowledged for many years. Developmental effects associated with female lead workers and wives of lead workers were well known during the 18th and 19th centuries, and much of what is taken for granted today regarding lead poisoning in children has been known for more than ninety years. None the less, production of lead compounds, mining and smelting of lead ore and secondary lead sources, and widespread use of lead-containing products continued to increase during the 20th century. These manufacturing, mining, and smelting activities resulted in the contamination of many industrial and residential areas. In addition, leaded gasoline and lead-based paint contributed to the dispersal of lead throughout the environment. During the 1970s and 1980s, federal agencies targeted programs and resources to reduce lead exposure in the United States. These primary prevention activities resulted in regulations governing air emissions, drinking water standards, the phase-out of lead in gasoline, and the banning of lead-based paint and leaded solder. Although these efforts have all contributed to reducing lead exposure to the general population, past uses have resulted in the contamination of many areas, many of which still have the potential for adversely affecting the public health.

## Introduction

One of the mandates of the Agency for Toxic Substances and Disease Registry (ATSDR) (under the Comprehensive Environmental Response, Compensation, and Liability Act, Section 104(i)(3), or Superfund) is to address the potential for adverse effects on public health resulting from lead exposure. Lead has been identified as a contaminant in at least 1,026 of the National Priorities List (NPL) sites and is currently ranked first on the Priority List of Hazardous Substances (ATSDR 1996a). Consequently, ATSDR must address public health concerns regarding lead exposure at hazardous waste sites. ATSDR’s specific responsibilities related to blood lead screening at lead-contaminated hazardous waste sites include: (1) evaluation of site-specific environmental lead exposure information, (2) identification of populations potentially exposed to lead, (3) decision about whether or not to conduct blood lead screening, (4) evaluation of blood lead screening results, and (5) determination of whether the U.S. Environmental Protection Agency’s (EPA) proposed site remediation plans are sufficient to protect public health.

Evaluation of these environmental data is associated with a high level of biomedical judgment regarding appropriate public health actions. In this manuscript, we describe a framework developed to guide such judgment and one that can be used to evaluate the need for a site-specific public health action, which may include blood lead screening. This approach utilizes regression analysis along with uptake parameters and potential results of exposure in an effort to estimate blood lead levels in at-risk populations.

Superfund specifically directs ATSDR to ascertain significant human exposure levels for hazardous substances. Minimal risk levels (MRLs) were developed as part of the strategy to address this mandate. An MRL is "an estimate of the daily human exposure to a dose of a chemical that is likely to be without an appreciable risk of adverse, noncancerous effects over a specified duration of exposure” (ATSDR 1996b) and is analogous to the reference doses and the reference concentrations developed by EPA. MRLs are derived from no-observed-adverse-effect levels or lowest-observed-adverse-effect levels and are intended to assist in determining the safety of communities near hazardous waste sites. For example, an exposure level below the MRL suggests that there is little likelihood of adverse, noncancer human health effects occurring, whereas an exposure level exceeding the MRL alerts the health assessor that a more detailed evaluation using site-specific and chemical-specific information is required. Although the database for lead is large, empirical data from which to obtain a threshold for the effects of lead are lacking. With no observable threshold yet identified, the derivation of conventional health assessment tools such as MRLs is not feasible (De Rosa et al. 1991). In addition, a great deal of the human health effects data are expressed in terms of blood lead (PbB) levels rather than exposure dose, the usual comparison value. Using more traditional methodologies would overlook this significant body of literature, as well as the Centers for Disease Control (CDC, now the Centers for Disease Control and Prevention) guidelines^1^. A predictive tool relating environmental levels to PbBs is needed.

1 The weight of evidence suggests that PbBs of "10–15 µg/dL and possibly lower" are the levels of concern (ATSDR 1993; Davis 1990; EPA 1986). The Department of Health and Human Services (DHHS) has determined that primary prevention activities should begin at blood lead levels of 10 µg/dL in children (CDC 1991).

In response to this mandate, the Agency has been seeking ways to further refine the tools necessary for assessing the public health implications from exposure to hazardous substances. MRLs provide a guidance for single routes of exposure to a single substance. But, clearly, multi-route, multi-substance exposure considerations are needed not only for lead but for other substances. To this end, a framework for determining significant human exposure levels was developed (Mumtaz et al. 1995). The development of health-based guidance for lead is consistent with this concept. It should be noted that this effort and others to associate environmental levels with PbBs and consequently make health decisions are simply screening tools. Many issues must be considered on a site-by-site basis and used in conjunction with this guidance. Some of these issues are outlined below.

Exposure and Bioavailability Issues. Primary routes of exposure to lead are via inhalation and ingestion. Lead exposure occurs through inhalation of airborne lead particles with deposition rates in adults of 30%–50% depending on factors such as particle size and ventilation rate (EPA 1986). Once deposited in the lower respiratory tract, lead appears to be almost completely absorbed (Morrow et al. 1980).

Oral intake of lead is a more important route of exposure for children and can occur from ingestion of contaminated food, soil, dust, water, or lead-based paint chips. For young children (1–6 years of age), soil and dust are important pathways for exposure. Ingestion of soil and dust can occur through normal hand-to-mouth activity. Lead-based paint, often found in older homes, and flaking or peeling off walls, can also contribute significantly to exposure in young children. Through normal aging and weathering, intact lead-based paint can contribute to the contamination of dust or soil

The extent and rate of gastrointestinal absorption of lead is mediated by several factors including fasting, physical and chemical form of lead, and dietary status of the individual (Aungst et al. 1981; Grobler et al. 1988; Baltrop and Meek 1979; Chamberlain et al. 1978; Mahaffey et al. 1982; Rabinowitz et al. 1976).

Animal studies indicate that nutritional deficiencies in a number of essential elements (e.g., calcium, iron, zinc, copper, phosphorus) may impact the toxicokinetic and toxicological behavior of lead (ATSDR 1993; Chaney et al. 1989). In infants and children, lead retention has been shown to be inversely correlated with calcium intake (Johnson and Tenuta 1979; Sorrell et al. 1977; Ziegler et al. 1978). Zinc has been shown to have a protective effect against lead toxicity in a number of animal species (Goyer 1986; Haeger-Aronsen et al. 1976; Brewer et al. 1985; Cerklewski and Forbes 1976).

The physical and chemical characteristics of the lead/soil matrix and the particular lead species have also been shown to affect the bioavailability of lead. Studies measuring lead concentration at various soil and dust particle sizes have shown that higher lead concentrations are often found in the smaller-sized fractions. The results of these studies have been summarized by Duggan and Inskip (1985). This is particularly important for young children because smaller particles (<100 µm in diameter) also tend to adhere more readily to hands. Additionally, lead from smaller particles is more readily absorbed from the gastrointestinal tract (Baltrop and Meek 1979). It has been suggested that lead at mining waste sites is less bioavailable and therefore poses less of a human health hazard than lead found at smelter sites or in urban areas (Hemphill et al. 1991; Steele et al. 1990). These differences in bioavailability have been attributed to these biochemical/ biophysical differences of the lead source. Lead particles at mining sites are typically of larger size and consist of the less soluble lead sulfides. However, recent data suggest that this may not always be the case and that a site-by-site evaluation is necessary to determine the lead hazards to the surrounding populations (Gulson et al. 1994; Mushak 1991). See Mushak (1991) for a review of physical/chemical issues regarding lead bioavailability.

Age is also an important factor in that young children absorb lead more efficiently than adults (50% versus 15%) (Chamberlain et al. 1978). Fasting has a significant effect on absorption of lead. Retention of ingested lead is about 60% under fasting conditions compared with 4% when lead is ingested with a balanced meal (James et al. 1985).

Behavioral factors must also be considered. The normal hand to mouth activity of young children results in an increase in lead intake from hand soil/dust particles. In addition, children who exhibit pica behavior are at increased risk because they may ingest more lead-contaminated soil/dust. Health assessors should also be aware of distinct sources of lead within a household or community, such as certain hobbies that would expose one to lead (e.g. using molten lead for casting ammunition, leaded solder for making stained glass, leaded glazes for pottery), the use of folk remedies or lead-glazed pottery, or eating imported canned foods that might contain elevated lead from lead solder used in the can seams.

## Approach

Numerous longitudinal and cross-sectional studies have attempted to correlate environmental lead levels with blood lead levels (Table 1). These studies have provided a number of regression analyses and corresponding slope factors (δ) for various media including air, soil, dust, water, and food. The specifics of each of these have been extensively discussed and evaluated elsewhere (Brunekreef 1984; Duggan and Inskip 1985; EPA 1986; Reagan and Silbergeld 1990; Xintaras 1992). In an attempt to use this valuable body of data, ATSDR has developed an integrated exposure regression analysis (Abadin and Wheeler, 1993). This approach utilizes slope values from select studies to integrate all exposures from various pathways, thus providing a cumulative exposure estimate expressed as total blood lead.

Table 1 Summary of blood slope factors from various environmental media

Population | Slope | Comments | Reference
[underlined: Air Slope Factors] | [underlined: µg/dL per µg Pb/m^3^]
Adults; N = 43 | 1.75 ± 0.35 | Experimental study; EPA analysis | Griffin et al. 1975
Adults; N=5 | 1.59–3.56 | Experimental study; EPA analysis | Rabinowitz et al. 1976
Adults; N=10 | 2.7 | Experimental study; EPA analysis | Chamberlain et al. 1978
Children; 1–18 years of age; N=831; 1,074 blood samples | 1.92 ± 0.60 | Omaha cross-sectional study; smelter | Angle et al. 1984
Children; N=148 | 2.46 ± 0.58 | Belgium cross-sectional study; smelter; EPA analysis | Roels et al. 1980
Children; N=880 | 1.53 ± 0.064 | Kellogg/Silver Valley cross-sectional study; EPA analysis; smelter | Yankel et al. 1977
Adult males; 5 groups, 30/group | 2.57 ± 0.04 | Cross-sectional study; air concentrations of 1 µg/m^3^ | Azar et al. 1975
Adult males; 5 groups, 30/group | 1.12 | Reanalysis of Azar 1975 by Snee 1982; at air concentration of 1 µg/m^3^ | Azar et al. 1975
Adult males; 5 groups, 30/group | 1–2.39 | Analysis of Azar 1975 by EPA; at 1 µg/m^3^ | Azar et al. 1975
Adults; N=44 | 1.14 | Occupational longitudinal study over 30 months; air concentration <30 µg/m^3^ | Hodgkins et al. 1992
[underlined: Water Slope Factors] | [underlined: µg/dL per µg Pb/L]
Infants, N=131 | 0.26 at <15 µg/L 0.04 at >15 µg/L | Scottish study of infants; EPA analysis | Lacey et al. 1985
Children, N=495 | 0.16 at <15 µg/L 0.03 at >15 µg/L | Scottish study; EPA analysis | Laxen et al. 1987
Adult males, N=7,735 | 0.06 | 24 British towns sampled; water lead levels <100 µg/L | Pocock et al. 1983
Adult Females, N=114 | 0.03 | Duplicate diet study; Ayr, Scotland; EPA analysis | Sherlock et al. 1982
[underlined: Diet Slope Factors:] | [underlined: µg/dL per µg Pb/day]
Infants and toddlers; N=29 | 0.24 | Breast-fed and formula-fed; EPA analysis | Ryu et al. 1983; EPA 1990
Adults; N=31 | 0.034--females | Duplicate diet study; Ayr, Scotland | Sherlock et al. 1982
Adults; N=15 | 0.014–0.017--males 0.018–0.022--females | Experimental study; blood leads were not allowed to equilibrate | Stuik et al. 1974
Adult males; N=15 | 0.027 | Experimental study | Cools et al. 1976
[underlined: Soil Slope Factors] | [underlined: µg/dL per µg Pb/kg]
Mixed | 0.002–0.016 | Review of the literature | Reagan and Silbergeld 1990
Children; 1–18 years of age; N=831; 1,074 blood samples | 0.0068 ± 0.00097 | Omaha study; urban/suburban | Angle et al. 1984
Children; 1–72 months of age; N=377; 926 blood leads | −0.00016–0.00223 (near house) 0.00073–0.0023 at curb) | New Haven, CT; EPA analysis. The largest slopes were from the children under 1 year | Stark et al. 1982
Children; N=880 | 0.0011 (avg. for all ages) 0.0025 (for 2–3 year olds) | Kellogg/Silver Valley cross-sectional study; smelter; EPA analysis | Yankel et al. 1977
U.S. males age 18–65 years old (NHANES III) | 0.001–0.003 | Slope derived from Monte Carlo analysis | Stern 1996
[underlined: Dust Slope Factors] | [underlined: µg/dL per mg Pb/kg]
Children; 1–18 years of age; N=831; 1074 blood samples | 0.00718 ± 0.00090 | Omaha study; urban/suburban; housedust | Angle et al. 1984
Children; 1–6 years of age; N=32 | 0.008 | Homes of lead workers; housedust | Baker 1977
Children; 2 years of age; N=82 | 0.004 | Area of high lead soil; housedust | Baltrop et al. 1974
Adults and children; N=80 | 0.0086–0.0096 (housedust); 0.0021–0.0067 (outside dust) | Smelter | Roberts et al. 1974
Children; N=377; 1–72 months of age; old); 0.00182 ± 926 blood lead levels | 0.00402 ± 0.0017 (0–1 year 0.00066 (2–3 years old) 0.00022±0.00077 (4– 7 years old) | New Haven, CT; EPA analysis | Stark et al. 1982

Source: adapted from Duggan and Inskip 1985; EPA 1986, 1989

The general form of the model is:

PbB=δ_S_TPb_S_ + δ_D_TPb_D_ + δ_W_TPb_W_ + δ_AO_TPb_AO_ + δ_AI_TPb_AI_ + δ_F_TPb_F_

- where,
  Pb_S_=soil lead concentration
  Pb_D_=dust lead concentration
  Pb_W_=water lead concentration
  Pb_AO_=outside air lead concentration
  Pb_AI_=inside air concentration
  Pb_F_=food lead concentration
  T=relative time spent
  δ=the respective slope factor for specific media

A worktable that can be used to calculate a cumulative exposure estimate on a site-specific basis is provided in Table 2. To use the table, environmental levels for outdoor air, indoor air, food, water, soil, and dust are needed. In the absence of such data (as may be encountered during health assessment activities), default values can be used. In most situations, default values will be background levels unless data are available to indicate otherwise. Based on the U.S. Food and Drug Administration’s (FDA’s) Total Diet Study data, lead intake from food for infants and toddlers is about 5 µg/day (Bolger et al. 1991). In some cases, a missing value can be estimated from a known value. For example, EPA (1986) has suggested that indoor air can be considered 0.03×the level of outdoor air. Suggested default values are listed in Table 3.

Empirically determined and/or default environmental levels are multiplied by the percentage of time one is exposed to a particular source and then multiplied by an appropriate regression slope factor. This assumes slope factor studies were based upon continuous exposure. The slope factors can be derived from regression analysis studies that determine PbBs for a similar route of exposure. Typically, these studies identify standard errors describing the regression line of a particular source of lead exposure. These standard errors can be used to provide an upper and lower confidence limit contribution of each source of lead to PbB. The individual source contributions can then be summed to provide an overall range estimate of PbB. While it is known that such summing of standard errors can lead to errors of population dynamics, detailed demographic analysis (e.g., Monte Carlo simulations) would likely lead to a model without much utility. As a screening tool, the estimates provided here have much greater utility than single value central tendency estimates, yet still provide a simple-to-use model that allows the health assessor an easy means to estimate source contributions to PbB.

As an example, Table 4 provides environmental monitoring data for a subset of data from the Multisite Lead and Cadmium Exposure Study (ATSDR 1995). Default values are used for air and dietary lead. The data are input as described in equation 1 with suggested slope factors from Table 2. The resulting media-specific contributions to PbB, the range of predicted PbBs, and the actual PbBs are given in Table 5.

The purpose of screening tools, such as MRLs or estimates derived from this approach, is to alert health assessors to substances that may pose risk to the exposed population. In addition, these approaches economize the use of resources by eliminating substances for which there is little likelihood of human health effects so that efforts can be concentrated on those compounds of importance. Interpretation of the results from Table 5 would indicate that the potential exists that children at sites B and C have elevated PbBs as defined by the CDC guidelines. Further action on these sites would, therefore, be warranted based on the individual site-specific demographic information and the CDC recommended follow-up services. These might include education, follow-up testing, and social services (CDC 1997). Results from site A, however, would indicate to the health assessor that the environmental data would not likely adversely affect PbBs of resident children; resources can then be shifted to the other substances at the site.

Table 2 Worktable for calculation of PbB from environmental and dietary lead

Media | Concentration | Relative Time Spent | Slope Factor | Blood Lead
Media | Concentration | Relative Time Spent | Slope Factor | Low | High
Outdoor Air
Outdoor Air
Indoor Air
Indoor Air
Food
Water
Soil
Soil
Dust
Dust
Total

Table 3 Suggested default values to be used for missing data

Media | Default | Reference
Outdoor Air | 0.1–0.2 µg/m^3^ | Eldred and Cahill 1994
Indoor Air | 0.03–0.06 µg/m^3^ (0.3×outdoor concentration) | EPA 1986
Food | 5 µg/day | Bolger et al. 1991
Water | 4 µg/L | EPA 1991
Soil | 10–70 mg/kg | Shacklette and Boerngen 1972
Dust | 10–70 mg/kg | Shacklette and Boerngen 1972

Table 4 Media concentrations for three sites: A, B, and C

| SITE
Media | A | B | C
Soil (mg/kg) | 290 | 768 | 580
Dust (mg/kg) | 383 | 580 | 560
Air (µg/m^3^) | 0.06–0.2 | 0.06–0.2 | 0.06–0.2
Water (µg/L) | 1 | 1 | 1
Food (µg/day) | 5 | 5 | 5

Table 5 Contribution of environmental lead to blood lead for three sites: A, B, and C

| SITE
Media | A contribution to PbB (µg/dL) | B contribution to PbB (µg/dL) | C contribution to PbB (µg/dL)
Soil | 1.1–2.8 | 3–7.4 | 2.3–5.6
Dust | 1.7–3.8 | 2.6–5.7 | 2.5–5.5
Air | 0.1–0.2 | 0.1–0.2 | 0.1–0.2
Water | 0.26 | 0.26 | 0.26
Food | 1.2 | 1.2 | 1.2
Predicted range of PbB (µg/dL) | 4.4–8.3 | 7–14.8 | 6.4–12.8
Actual PbB | 4.8 | 10.6 | 13.1

Slope values used were based on Angle et al. (1984): soil = 0.0068 ± 3SE; dust = 0.00718 ± 3SE; air = 1.92 ± 3SE.

Slope value for water was 0.26, based on Lacey et al. 1985 (reanalyzed by EPA 1986).

Slope value for food was 0.24, based on Ryu et al. 1983 (reanalyzed by Marcus in EPA 1990).

Default concentrations were used for air and food.

## Summary and Discussion

A number of methods and models have been used at sites to estimate potential risks from exposure to lead. One method is the use of prevalence data for estimating PbBs. In this case, PbB measurements can be made at a site and extrapolated to other sites with similar environmental and demographic data. Limitations of this method include site-to-site variability with respect to, among other things, children’s behavioral patterns, age, and bioavailability issues. Estimation of past exposures can be problematic because of redistribution of Pb out of the blood compartment since PbB is only an indicator of recent exposure (<90 days).

More traditional approaches have calculated exposure doses from a particular medium via a specific route (ATSDR, 1992). Such exposure doses can then be compared with a reference value derived for the same substance via the same route of exposure. Usual assumptions are ingestion rates of 100 mg dust/day and 200 mg soil/day, child body weight of 15 kg, and continuous exposure scenarios. This approach assumes a threshold for the effects of lead and does not reflect the fullest possible use of the wealth of human data on PbBs.

Pharmacokinetic models have been developed that attempt to relate environmental levels to PbBs (Leggett 1993; O’Flaherty 1995). The Integrated Exposure Uptake Biokinetic Model (IEUBK) developed by EPA is one of the most extensive efforts to date to make population-based predictions of PbBs based upon environmental data. The model incorporates both exposure/uptake parameters and a biokinetic component to estimate the PbB distribution in the exposed population (EPA 1994).

The framework described here provides a useful screening tool. Preliminary efforts to test its predictive power have shown promise (unpublished data). The framework’s strengths lie in its simplicity and flexibility to take into consideration environmental and biological variability between sites through the selection of slope factors from similar sites. For example, slope factors from a lead mining study can be used to address concerns at a mining community or, as more refined regression coefficients become available, they can be used in a site-specific manner to assist in making appropriate decisions. The framework also offers a simple approach that allows the health assessor to readily identify factors that may be contributing to elevated PbBs. In this manner, it provides for multi-media evaluation of all source contributions and utilizes a basic approach for determining significant human effect levels. This helps the health assessor determine source contributions of most significance and suggests plausible remediation avenues. These insights, coupled with biomedical judgment, can serve as valuable screening tools to identify those sites meriting further evaluation.

## References

Abadin HG, Wheeler JS. Guidance for risk assessment of exposure to lead: A site-specific, multimedia approach. Hazardous waste and public health: International congress on the health effects of hazardous waste. Princeton, NJ. Princeton Scientific Publishing Company, Inc. 1993:477-485.
Angle CR, Marcus A, Cheng I-H, McIntire MS. Omaha childhood blood lead and environmental lead: A linear total exposure model. Environ Res. 1984;35:160-170. [pmid: 6489285].
ATSDR. Public health assessment guidance manual. Atlanta, GA. US Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry. 1992.
ATSDR. Toxicological profile for lead. Atlanta, GA. US Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry. 1993.
ATSDR. Multisite lead and cadmium exposure study with biological markers incorporated. Atlanta, GA. US Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry. 1995.
ATSDR. 1995 CERCLA priority list of hazardous substances that will be the subject of toxicological profiles and support document. Atlanta, GA. US Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry. 1996a.
ATSDR. Minimal risk levels for priority substances and guidance for derivation; republication. Federal Register. June. 27. 1996b;Vol. 61(No. 125). 1996.
Aungst BJ, Dolce JA, Fung H-L. The effect of dose on the disposition of lead in rats after intravenous and oral administration. Toxicol Appl Pharmacol. 1981;61:48-57. [pmid: 7292502].
Azar A, Snee RD, Habibi K. Griffin TB, Knelson JH, editors. An epidemiologic approach to community air lead exposure using personal air samplers. Lead. Stuttgart, West Germany. Georg Thieme Publishers. 1975:254-290.
Baker EL, Hayes CG, Landrigan PH, et al. A nationwide survey of heavy metal absorption in children living near primary copper, lead, and zinc smelters. Am J Epidemiol. 1977;106(4):261-273. [pmid: 910795].
Barltrop D, Strehlow CD, Thorton I, et al. Significance of high soil lead concentrations for childhood lead burdens. Environ Health Perspect. 1974;7:75-82. [pmid: 4831150].
Barltrop D, Meek F. Effect of particle size on lead absorption from the gut. Arch Environ Health. 1979;34:280-285. [pmid: 475473].
Bolger PM, Carrington CD, Capar SG, Adams MA. Reductions in dietary lead exposure in the United States. Chemical Speciation and Bioavailability. 1991;3(3/4):31-36.
Brewer GJ, Hill GM, Dick RD, et al. Interactions of trace elements: Clinical significance. J Am Coll Nutr. 1985;4:33-38. [pmid: 3886759].
Brunekreef BD. The relationship between air lead and blood lead in children: A critical review. Sci Total Environ. 1984;38:79-123. [pmid: 6395339].
Cerklewski FL, Forbes RM. Influence of dietary zinc on lead toxicity in the rat. J Nutr. 1976;106:689-696. [pmid: 1262976].
Chaney RL, Mielke HW, Sterrett SB. Speciation, mobility and bioavailability of soil lead. Environ Geochem Health. Suppl. 1989;9:105-129.
CDC. Preventing lead poisoning in young children. Atlanta, GA. US Department of Health and Human Services, Public Health Service, Centers for Disease Control. 1991.
CDC. Screening young children for lead poisoning: Guidance for state and local public health officials-DRAFT. Centers for Disease Control and Prevention. Atlanta, GA. US Department of Health and Human Services, Public Health Service. 1997.
Cools A, Salle HJA, Verberk MM, et al. Biochemical response of male volunteers ingesting inorganic lead for 49 days. Int Arch Occup Environ Health. 1976;38:129-139. [pmid: 1002305].
Davis MJ. Risk assessment of the developmental neurotoxicity of lead. Neurotoxicology. 1990;11:285-292. [pmid: 2234545].
De Rosa CT, Choudhury H, Peirano WB. An integrated exposure/pharmacokinetic based approach to the assessment of complex exposures: Lead: A case study. Toxicol Ind Health. 1991;7(4):231-247. [pmid: 1776155].
Duggan MJ, Inskip MJ. Childhood exposure to lead in surface dust and soil: A community health problem. Public Health Rev. 1985;13:1-54. [pmid: 2422703].
Eldred RA, Cahill TA. Trends in elemental concentrations of fine particles at remote sites in the United Sates of America. Atmos Environ. 1994;28:1009-1019.
EPA. Air quality criteria for lead. Research Triangle Park, NC. US Environmental Protection Agency, Office of Research and Development, Office of Health and Environmental Assessment, Environmental Criteria and Assessment Office. 1986. EPA 600/8-83-028F.
EPA. Maximum contaminant level goals and national primary drinking water regulations for lead and copper. Federal Register. 1991;56:26461-26564.
EPA. Uptake of lead from formula and food by infants: Reanalysis of the Ryu et al. data. Draft final report. US Environmental Protection Agency, Office of Pesticides and Toxic Substances Exposure Evaluation Division, Office of Toxic Substances. 1990.
EPA. Guidance manual for integrated exposure uptake biokinetic model for lead in children. US Environmental Protection Agency, Office of Solid Waste and Emergency Response. 1994. EPA/540/R-93/081.
Goyer RA. Klaassen CD, et al., editors. Toxic effect of metals. Casarett and Doull's Toxicology: The basic science of poisons. 3rd ed. New York, NY. Macmillan Publishing Co. 1986:582-588. 598. 605.
Griffin TB, Coulston F, Golberg L, et al. Griffin TB, Knelson JG, editors. Clinical studies on men continuously exposed to airborne particulate lead. Lead. Stuttgart, West Germany. Georg Thieme Publisher. 1975:221-240.
Grobler SR, Rossouw RJ, Kotze D. Effect of airborne lead on the blood lead levels of rats. S Afr J Sci. 1988;84:260-262.
Gulson BL, Davis JJ, Mizon KJ, Korsch MJ, Law AJ. Lead bioavailability in the environment of children: Blood lead levels in children can be elevated in a mining community. Arch Environ Health. 1994;49(5):326-331. [pmid: 7944562].
Haeger-Aronsen B, Schutz A, Abdulla M. Antagonistic effect in vivo of zinc on inhibition of δaminolevulinic acid dehydratase by lead. Arch Environ Health. 1976;31(4):215-220. [pmid: 942264].
Heard MJ, Chamberlain AC. Effect of minerals and food on uptake of lead from the gastrointestinal tract in humans. Hum Toxicol. 1982;1:441-415.
Hemphill CP, Ruby MV, Beck BD, Davis A, Bergstrom PD. The bioavailability of lead in mining wastes: physical/chemical considerations. Chem Speciation and Bioavailability. 1991;3(3/4):135-148.
Hodgkins DG, Robins TG, Hinkamp DL, et al. A longitudinal study of the relation of lead in blood to lead in air concentrations among battery workers. Br J Ind Med. 1992;49:241-248. [pmid: 1571294].
James HM, Hilburn ME, Blair JA. Effects of meals and meal times on uptake of lead from the gastrointestinal tract in humans. Hum Toxicol. 1985;4:401-407. [pmid: 4018820].
Johnson NE, Tenuta K. Diets and lead blood levels of children who practice pica. Environ Res. 1979;18:369-376. [pmid: 583140].
Lacey RF, Moore MR, Richards WN. Lead in water, infant diet and blood: The Glasgow duplicate diet stud. Sci Total Environ. 1985;41:235-257. [pmid: 4035342].
Laxen DP, Raab GM, Fulton M. Children's blood lead and exposure to lead in household dust and water--a basis for an environmental standard for lead in dust. Sci Total Environ. 1987;66:235-244. [pmid: 3685951].
Leggett RW. An age-specific kinetic model of lead metabolism in humans. Environ Health Perspect. 1993;101:598-616. [pmid: 8143593].
Mahaffey KR, Rosen JF, Chesney RW, et al. Association between age, blood lead concentration, and serum 1,25-dihydroxycholecalciferol levels in children. Am J Clin Nutr. 1982;35:1327-1331. [pmid: 6896257].
Morrow PE, Beiter H, Amato F, Gibb FR. Pulmonary retention of lead: An experimental study in man. Environ Res. 1980;21:373-384. [pmid: 7408808].
Mumtaz MM, Cibulas W, De Rosa CT. An integrated framework to identify significant human exposures (SHELs). Chemosphere. 1995;31(1):2485-2498. [pmid: 7670861].
Mushak P. Gastro-intestinal absorption of lead in children and adults: Overview of biological and biophysico-chemical aspects. Chem Speciation and Bioavailability. 1991;3(3/4):87-104.
O'Flaherty EJ. Physiologically based models for bone-seeking elements. V Lead absorption and disposition in childhood. Toxicol Appl Pharmacol. 1995;131:297-308. [pmid: 7716770].
Pocock SJ, Shaper AG, Walker M, et al. Effects of tap water lead, water hardness, alcohol, and cigarettes on blood lead concentrations. J Epidemiot Communitv Health. 1983;37:1-7.
Rabinowitz MB, Wetherill GW, Kopple JD. Kinetic analysis of lead metabolism in healthy humans. J Clin Invest. 1976;58:260-270. [pmid: 783195].
Reagan PL, Silbergeld EK. Establishing a health based standard for lead in residential soils. Trace Subst Environ Health. 1990;23:199-238.
Roberts TM, Hutchinson TC, Paciga J. Lead contamination around secondary smelters: Estimation of dispersal and accumulation by humans. Science. 1974;186:1120-1123. [pmid: 4469700].
Roels HA, Buchet J-P, Lauwerys RR, et al. Exposure to lead by the oral and the pulmonary routes of children living in the vicinity of a primary lead smelter. Environ Res. 1980;22:81-94. [pmid: 7418689].
Ryu JE, Ziegler EE, Nelson SE, Fomon SJ. Dietary intake of lead and blood lead concentration in early infancy. Am J Dis Child. 1983;137:886-891. [pmid: 6613955].
Shacklette HT, Boerngen JG. Elemental composition of surficial materials in the conterminous United States. Washington DC. US Department of the Interior, Geological Survey; Geological Survey professional paper no. 1270. 1972.
Sherlock JC, Smart G, Forbes GI, et al. Assessment of lead intakes and dose-response for a population in Ayr exposed to a plumbosolvent water supply. Human Toxicol. 1982;1:115-122.
Sorrell M, Rosen JF, Roginsky M. Interactions of lead, calcium, vitamin D, and nutrition in lead burdened children. Arch Environ Health. 1977;32:160-164. [pmid: 889354].
Stark AD, Quah RF, Meigs JW, et al. The relationship of environmental lead to blood-lead levels in children. Environ Res. 1982;27:372-383. [pmid: 7084166].
Steele MJ, Beck BD, Murphy BL, Strauss HS. Assessing the contribution from lead in mining wastes to blood lead. Regul Toxicol Pharmacol. 1990;11:158-190. [pmid: 2185511].
Stern AH. Derivation of a target concentration of Pb in soil based on elevation of adult blood pressure. Risk Analysis. 1996;16:201-210. [pmid: 8638039].
Stuik EJ. Biological response of male and female volunteers to inorganic lead. Int Arch Arbeitsmed. 1974;33:83-97. [pmid: 4850778].
Xintaras C. Analysis paper: Impact of lead-contaminated soil on public health. Atlanta, GA. US Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry. 1992.
Yankel AJ, von Lindern IH, Walter SD. The Silver Valley lead study: The relationship of childhood lead poisoning and environmental exposure. J Air Pollut Contr Assoc. 1977;27:763-767.
Ziegler EE, Edwards BB, Jensen RL, Mahaffey KR, Fomon SJ. Absorption and retention of lead by infants. Pediatr Res. 1978;12:29-34. [pmid: 643372].