# CHAPTER 8 REFERENCES

Aldis H, Osbomy J, Wolf F. 1983. Investigation of soil and water contamination at Western Processing, King County, Washington. In: National conference on management of uncontrolled hazard waste sites: October 31-November 2, 1983. Washington, DC: Hazardous Materials Control Research Institute, 43–53.
Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York, NY: Marcel Dekker, Inc., 9–25.
Andersen ME, Gargas M, Jones R, 1980. Determination of the kinetic constants for metabolism of inhaled toxicants in vivo using gas uptake measurements. Toxicol Appl Pharmacol 54:100–116. 10.1016/0041-008X(80)90011-3.7394779
Ashley DL, Bonin MA, Cardinali FL, 1994. Blood concentrations of volatile organic compounds in a nonoccupationally exposed US population and in groups with suspected exposure. Clin Chem 40(7 Pt 2):1401–1404. 10.1093/clinchem/40.7.1401.8013127
Atkinson R, Carter WPL. 1984. Kinetics and mechanisms of gas-phase reactions of ozone with organic compounds under atmospheric conditions. Chem Rev 84:437–470. 10.1021/cr00063a002.
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Fed Reg 54(174):37618–37634.
ATSDR. 2010. Analyses and historical reconstruction of groundwater flow, contaminant fate and transport, and distribution of drinking water within the service areas of the Hadnot Point and Holcomb Boulevard water treatment plants and vicinities, U.S. Marine Corps Base Camp Lejeune, North Carolina. Chapter C: Occurrence of selected contaminants in groundwater at installation restoration program sites. Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/sites/lejeune/docs/chapter_c_hadnotpoint.pdf. June 6, 2022.
ATSDR. 2012. Health consultation: MLC former Delphi Division property off-site vapor intrusion investigation Livonia (Wayne County), Michigan. Agency for Toxic Substances and Disease Registry. EPA # MID005356621.
ATSDR. 2022a. 1,2-Dichloroethene. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/SPL/resources/index.html. June 24, 2022.
ATSDR. 2022b. Sanders2015 HLCs used in SHOWER Model v3 and PHAST. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
Ausbel R, Wijnen MHJ. 1975. Primary steps in the photolysis of cis-1,2-dichloroethylene. Int J Chem Kinet 75:739–751. 10.1002/kin.550070510.
Aylward LL, Kirman CR, Blount BC, 2010. Chemical-specific screening criteria for interpretation of biomonitoring data for volatile organic compounds (VOCs) - Application of steady-state PBPK model solutions. Regul Toxicol Pharmacol 58(1):33–44. 10.1016/j.yrtph.2010.05.011.20685286
Bagley DM, Gossett JM. 1990. Tetrachloroethylene transformation to trichloroethylene and cis-1,2-dichloroethylene by sulfate-reducing enrichment cultures. Appl Env Micro 56(8):2511–2516.
Barber LB, Thurman EM, Schroeder MP, 1988. Long-term fate of organic micropollutants in sewage-contaminated groundwater. Environ Sci Technol 22(2):205–211. 10.1021/es00167a012.19995023
Barkley J, Bunch J, Bursey JT, 1980. Gas chromatography mass spectrometry computer analysis of volatile halogenated hydrocarbons in man and his environment-A multimedia environmental study. Biomed Mass Spectrom 7(4):139–147. 10.1002/bms.1200070402.7448328
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486. 10.1016/0273-2300(88)90047-5.3222488
Barnes DW, Sanders VM, White KL, 1985. Toxicology of trans-1,2-dichloroethylene in the mouse. Drug Chem Toxicol 8(5):373–392. 10.3109/01480548509041065.4064949
Barrio-Lage G, Parsons FZ, Nassar RS, 1986. Sequential dehalogenation of chlorinated ethenes. Environ Sci Technol 20(1):96–99. 10.1021/es00143a013.22300158
Baum G, Oppenlander T. 1995. Vacuum-UV-oxidation of chloroorganic compounds in an excimer flow through photoreactor. Chemosphere 30(9):1781–1790. 10.1016/0045-6535(95)00062-D.
Bennett H. 1981. 1,2-Dichloroethene. In: Encyclopedia of chemical trade names and synonyms. Vol. I. New York, NY: Chemical Publishing Co., 37.
Bhopale KK, Falzon M, Ansari GA, 2014. Alcohol oxidizing enzymes and ethanol-induced cytotoxicity in rat pancreatic acinar AR42J cells. In Vitro Cell Dev Biol Anim 50(4):373–380. 10.1007/s11626-013-9700-7.24281792
Blackburn AC, Tzeng HF, Anders MW, 2000. Discovery of a functional polymorphism in human glutathione transferase zeta by expressed sequence tag database analysis. Pharmacogenetics 10(1):49–57. 10.1097/00008571-200002000-00007.10739172
Blackburn AC, Coggan M, Tzeng HF, 2001. GSTZ1d: a new allele of glutathione transferase zeta and maleylacetoacetate isomerase. Pharmacogenetics 11(8):671–678. 10.1097/00008571-200111000-00005.11692075
Boateng K, Evers PC, Testa SM. 1984. Ground water contamination of two production wells: A case history. Ground Water Monit Remediat 4(2):24–31. 10.1111/j.1745-6592.1984.tb00879.x.
Bonse G, Urban T, Reichert D, 1975. Chemical reactivity, metabolic oxirane formation and biological reactivity of chlorinated ethylenes in the isolated perfused rat liver preparation. Biochem Pharmacol 24(19):1829–1834. 10.1016/0006-2952(75)90468-2.1233985
Brenner D. 2010. Results of a long-term study of vapor intrusion at four large buildings at the NASA Ames Research Center. J Air Waste Manag Assoc 60(6):747–758. 10.3155/1047-3289.60.6.747.20565001
Brock WJ. 1990. Acute toxicity studies with trans-1,2-dichloroethylene (DCE). J Am Coll Toxicol 1:10–11.
Broholm K, Ludvigsen L, Jensen TF, 2005. Aerobic biodegradation of vinyl chloride and cis-1,2-dichloroethylene in aquifer sediments. Chemosphere 60(11):1555–1564. 10.1016/j.chemosphere.2005.02.056.16083761
Bronzetti G, Bauer C, Corsi C, 1984. Comparative genetic activity of cis- and trans-1,2-dichloroethylene in yeast. Teratog Carcinog Mutagen 4(4):365–375. 10.1002/tcm.1770040406.6149629
Brown KW, Donnelly KC. 1988. An estimation of the risk associated with the organic constituents of hazardous and municipal waste landfill leachates. Hazard Waste Hazard Mater 55:1–30. 10.1089/hwm.1988.5.1.
Bruce BW, McMahon PB. 1996. Shallow ground-water quality beneath a major urban center: Denver, Colorado, USA. J Hydrol 186(1–4):129–151. 10.1016/s0022-1694(96)03031-4.
Burback BL, Perry JJ. 1993. Biodegradation and biotransformation of groundwater pollutant mixtures by Mycobacterium vaccae. Appl Environ Microbiol 59(4):1025–1029. 10.1128/aem.59.4.1025-1029.1993.8476280
Burk T, Zarus G. 2013. Community exposures to chemicals through vapor intrusion: a review of past ATSDR public health evaluations. J Environ Health 75(9):36–41.
Bysshe SE. 1982. Bioconcentration factor in aquatic organisms. In: Lyman WJ, Reehl WF, Rosenblatt DH, eds. Handbook of chemical property estimation methods. New York, NY: McGraw Hill Book Co., 5.1–5.30.
Cantelli-Forti G, Bronzetti G. 1988. Mutagenesis and carcinogenesis of halogenated ethylenes. Ann N Y Acad Sci 534:679–693. 10.1111/j.1749-6632.1988.tb30158.x.3389684
CDC. 2021. Fourth national report on human exposure to environmental chemicals: Updated tables, March 2021. Volume two: NHANES 2011–2016. Atlanta, GA: Centers for Disease Control and Prevention. https://www.cdc.gov/exposurereport/index.html. June 23, 2022.
Cerna M, Kypenova H. 1977. Mutagenic activity of chloroethylene analyzed by screening system tests. Mutat Res 46:214–215. 10.1016/0165-1161(77)90060-7
Clark RM, Fronk CA, Lykins BW. 1988. Removing organic contaminants from groundwater. Environ Sci Technol 22(10):1126–1130. 10.1021/es00175a001.22148601
Clewell HJ. 1995. The application of physiologically based pharmacokinetic modeling in human health risk assessment of hazardous substances. Toxicol Lett 79(1–3):207–217. 10.1016/0378-4274(95)03372-r.7570658
Clewell HJ, Andersen ME. 1994. Physiologically-based pharmacokinetic modeling and bioactivation of xenobiotics. Toxicol Ind Health 10(1–2):1–24. 10.1177/074823379401000101.7570610
Cline PV, Viste DR. 1985. Migration and degradation patterns of volatile organic compounds. Waste Manage Res 3:351–360. 10.1016/0734-242X(85)90128-4.
Cole RH, Frederick RE, Healy RP. 1984. Preliminary findings of the priority pollutant monitoring project of the nationwide urban runoff program. J Water Pollut Control Fed 56:898–908.
Confidential. 1999. trans-1,2-Dichloroethylene and cis-1,2-dichloroethylene: inhalation median lethal concentration (LC50) study in rats. Confidential. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. https://chemview.epa.gov/chemview/chemicaldata.do?sourceId=6&chemicalDataId=47144568&chemicalId=99605. April 8, 2024.
Confidential. 2014. In vitro mammalian cell forward gene mutation (CHO/HPRT) assay with duplicate cultures. Confidential. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. https://chemview.epa.gov/chemview/chemicaldata.do?sourceId=6&chemicalDataId=47144568&chemicalId=99605. April 8, 2024.
Confidential. 2015a. trans-1,2-Dichloroethylene: aromatase (human recombinant) assay. Confidential. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. https://chemview.epa.gov/chemview/chemicaldata.do?sourceId=6&chemicalDataId=47144568&chemicalId=99605. April 8, 2024.
Confidential. 2015b. Steroidogenesis (human cell line -H295R). Confidential. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. https://chemview.epa.gov/chemview/chemicaldata.do?sourceId=6&chemicalDataId=47144568&chemicalId=99605. April 8, 2024.
Confidential. 2015c. Bacterial reverse mutation assay. Confidential. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. https://chemview.epa.gov/chemview/chemicaldata.do?sourceId=6&chemicalDataId=47144568&chemicalId=99605. April 8, 2024.
Costa AK, Ivanetich KM. 1982. The 1,2-dichloroethylenes: Their metabolism by hepatic cytochrome P-450 in vitro. Biochem Pharmacol 31:2093–2102. 10.1016/0006-2952(82)90426-9.7115427
Costa AK, Ivanetich KM. 1984. Chlorinated ethylenes: Their metabolism and effect on DNA repair in rat hepatocytes. Carcinogenesis 5:1629–1636. 10.1093/carcin/5.12.1629.6499114
Crebelli R, Andreoli C, Carere A, 1995. Toxicology of halogenated aliphatic hydrocarbons: Structural and molecular determinants for the disturbance of chromosome segregation and the induction of lipid peroxidation. Chem Biol Interact 98(2):113–129. 10.1016/0009-2797(95)03639-3.8548852
Crebelli R, Carere A, Leopardi P, 1999. Evaluation of 10 aliphatic halogenated hydrocarbons in the mouse bone marrow micronucleus test. Mutagenesis 14(2):207–215. 10.1093/mutage/14.2.207.10229923
Csandy GA, Laib RJ, Filser JG. 1995. Metabolic transformation of halogenated and other alkenes-a theoretical approach. Estimation of metabolic reactivities for in vivo conditions. Toxicol Lett 75(1–3):217–223. 10.1016/0378-4274(94)03174-6.
Dahlberg JA. 1969. The non-sensitized photo-oxidation of trichlorethylene in air. Acta Chemica Scandinavica 23:3081–3090.
De Ceaurriz J, Desiles JP, Bonnet P, 1983. Concentration-dependent behavioral changes in mice following short-term inhalation exposure to various industrial solvents. Toxicol Appl Pharmacol 67(3):383–389. 10.1016/0041-008x(83)90322-8.6845368
Dever RJ. 1986. Responding to industrial contamination of groundwater: A case study. J Am Water Works Assoc 78(9):82–86. 10.1002/j.1551-8833.1986.tb05814.x.
Dilling WL. 1977. Interphase transfer processes. II. Evaporation rates of chloromethanes, ethanes, propanes, and propylenes from dilute aqueous solutions. Comparisons with theoretical predictions. Environ Sci Technol 11:405–409. 10.1021/es60127a009.
DOE. 2024a. Protective action criteria (PAC) based on AEGLs, ERPGs, or TEELs. U.S. Department of Energy. https://edms3.energy.gov/pac/TeelDocs. September 13, 2024.
DOE. 2024b. Definition of PACs (AEGLs, ERPGs or TEELs). U.S. Department of Energy. https://edms3.energy.gov/pac/TeelDef. September 13, 2024.
DOI. 1983. Organics transported through selected geological media: Assessment of organics transported away from industrial waste disposal sites. Springfield, VA: U.S. Department of the Interior. PB83224246.
Dow Chemical Company. 1960. Results of range finding toxicological tests on 1,2-dichloroethylene, mixed isomers, with cover letter dated 05/10/94 (sanitized). Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0557246. 86940000B36S. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0557246.xhtml. October 18, 2022.
Dow Chemical Company. 1994. The toxicity of 1,2-dichloroethylene as determined by repeated exposures on laboratory animals, with cover letter dated 05/10/94 (sanitized). Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0557247. 86940000837S. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0557247.xhtml. October 18, 2022.
Dreher EL, Torkelson TR, Beutel KK. 2012. Chlorethanes and chloroethylenes. In: Ullmann's encyclopedia of industrial chemistry. Vol. 8. Hoboken, NJ: John Wiley & Sons, Inc., 720–788. 10.1002/14356007.o06_o01.
DuPont. 1988a. Acute dermal toxicity study of trans-1,2-dichloroethylene in rabbits with cover letter dated 05/10/94 (sanitized). E.I. Dupont Denemours & Co. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0557172. 86940000762S. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0557172.xhtml. October 18, 2022.
DuPont. 1988b. Skin irritation test in rabbits of trans-1,2-dichloroethylene with cover letter dated 05/10/94 (sanitized). E.I. Dupont Denemours & Co. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0557174. 86940000764S. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0557174.xhtml. October 18, 2022.
DuPont. 1988c. Eye irritation test in rabbits of trans-1,2-dichloroethylene with cover letter dated 05/10/94 (sanitized). E.I. Dupont Denemours & Co. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0557173. 86940000763S. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0557173.xhtml. September 16, 2024.
DuPont. 1998. trans-1,2-Dichloroethylene: 90-day inhalation toxicity study in rats. E.I. du Pont de Nemours and Company. Submitted to the U.S. Environmental Protection Agency. Dupont HL-1998–00952. https://www.regulations.gov/comment/EPA-HQ-OPPT-2018-0465-0009. August 23, 2022.
DuPont. 1999. Initial submission: Letter from DuPont Haskell Laboratory to U.S. EPA re results of 4-hour inhalation median lethality study (LC50) in rats w/cis-1,2-dichloroethylene, dated 8/26/99. DuPont Chemical. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0559785. 88990000257. 8EHQ089914538. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0559785.xhtml. October 18, 2022.
Ehlke TA, Imbrigiotta T, Wilson BH, 1992. Biotransformation of cis-1,2-dichloroethylene in aquifer material from Picattiny Arsenal, Morris County, New Jersey. In: Mallard GE, Aronson DA, eds. U.S. Geological Survey toxic substances hydrology program-proceedings of the technical meeting, Monterey, California, March 11–15, 1991. WRI 914034. Reston, VA: U.S. Geological Survey, 689–697. 10.3133/wri914034.
Eisenreich SJ, Looney BB, Thornton JD. 1981. Airborne organic contaminants of the Great Lakes ecosystem. Environ Sci Tech 15:30–38. 10.1021/es00083a002.
El-Masri HA, Mumtaz MM, Yushak ML. 2004. Application of physiologically-based pharmacokinetic modeling to investigate the toxicological interaction between chlorpyrifos and parathion in the rat. Environ Toxicol Pharmacol 16(1–2):57–71. 10.1016/j.etap.2003.10.002.21782694
EPA. 1975. Preliminary assessment of suspected carcinogens in drinking water. Interim report to Congress, June, 1975. Washington, DC: U.S. Environmental Protection Agency. PB250961. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=91012F6P.txt. October 18, 2022.
EPA. 1976. Frequency of organic compounds identified in water. Athens, GA: U.S. Environmental Protection Agency. EPA600476062. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9100PLS3.txt. October 18, 2022.
EPA. 1978. Quantification of chlorinated hydrocarbons in previously collected air samples. U.S. Environmental Protection Agency. EPA450378112. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9100IDU1.txt. June 30, 2022.
EPA. 1979a. Water related environmental fate of 129 priority pollutants. Vol II. Washington, DC: U.S. Environmental Protection Agency. EPA440479029B. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=2000K6JL.txt. July 1, 2022.
EPA. 1979b. Sources of toxic pollutants found in influents to sewage treatment plants. Washington, DC: U.S. Environmental Protection Agency. EPA440481008. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9101UZJP.txt. August 23, 2022.
EPA. 1980a. Ambient water quality criteria document for DCE. U.S. Environmental Protection Agency. EPA440580041. https://www.epa.gov/sites/default/files/2019-03/documents/ambient-wqc-dichloroethylenes-1980.pdf. October 18, 2022.
EPA. 1980b. Treatability manual. Vol. 1. Treatability data. Washington, DC: U.S. Environmental Protection Agency. PB80223050. EPA600880042. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=30005R3P.txt. October 18, 2022.
EPA. 1981. Engineering handbook for hazardous waste incineration. Washington, DC: U.S. Environmental Protection Agency. SW889. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=2000KAVZ.txt. June 24, 2022.
EPA. 1982a. Aquatic fate process data for organic priority pollutants. Washington, DC: U.S. Environmental Protection Agency. EPA440481014. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9100O12M.txt. October 18, 2022.
EPA. 1982b. 1,2-Dichloroethene. Volatile organic chemical in the atmosphere: An assessment of available data. Research Triangle Park, NC: U.S. Environmental Protection Agency. PB83195503. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB83195503.xhtml. September 16, 2024.
EPA. 1983. Measurements of hazardous organic chemicals in the ambient atmospheric. Menlo Park, CA: U.S. Environmental Protection Agency. PB83156935. EPA600383002. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=91005A4X.txt. October 18, 2022.
EPA. 1984. Data acquisition for environmental transport and fate screening. Menlo Park, CA: U.S. Environmental Protection Agency. EPA600684010. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9101BZUU.txt. October 18, 2022.
EPA. 1985. Superfund record of decision (EPA Region 10): Ponders Corner Site, Washington (second remedial action), September 1985. U.S. Environmental Protection Agency. PB86133964. EPARODRlO85006. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB86133964.xhtml. September 16, 2024.
EPA. 1986a. Superfund record of decision (EPA Region 8): Marshall Landfill Site, Boulder County, Colorado, September 1986 report. U.S. Environmental Protection Agency. EPARODR0886008.
EPA. 1986b. Superfund record of decision (EPA Region 5): Forest Waste Disposal Site, Genesee County, Michigan, June 1986. U.S. Environmental Protection Agency. EPARODR058603.
EPA. 1986c. Superfund record of decision (EPA Region 2): Lang Property, Pemberton Township, New Jersey, September 1986. U.S. Environmental Protection Agency. EPARODR028603.
EPA. 1986d. Superfund record of decision (EPA Region 4): Hollingsworth Solderless Terminal Company Site, Fort Lauderdale, Florida, April 1986. U.S. Environmental Protection Agency. EPARODR048600.
EPA. 1987. Superfund record of decision (EPA Region 2): Vega Alta Public Supply-Wells, Puerto Rico (first remedial action), September 1987. U.S. Environmental Protection Agency. PB88185764. EPARODRO287050.
EPA. 1988. Land disposal restrictions. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268. https://www.ecfr.gov/current/title-40/chapter-I/subchapter-I/part-268. September 16, 2024.
EPA. 1996. Method 8260B: Volatile organic compounds by gas chromatography/mass spectrometry (GC/MS). Hazardous waste test methods. U.S. Environmental Protection Agency. SW-846. https://19january2017snapshot.epa.gov/sites/production/files/2015-12/documents/8260b.pdf. August 23, 2022.
EPA. 1999. Compendium method TO-17: Determination of volatile organic compounds in ambient air using active sampling onto sorbent tubes. Compendium of methods for the determination of toxic organic compounds in ambient air. Cincinnati, OH: U.S. Environmental Protection Agency. EPA625R96010b. https://www.epa.gov/sites/default/files/2019-11/documents/to-17r.pdf. October 18, 2022.
EPA. 2001. Occurrence of unregulated contaminants in public water systems: An initial assessment. U.S. Environmental Protection Agency. EPA815P00001. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P1009TXB.txt. June 13, 2022.
EPA. 2002. Method 8265: Volatile organic compounds in water, soil, soil gas, and air by direct sampling ion trap mass spectrometry (DSITMS). Hazardous waste test methods. U.S. Environmental Protection Agency. SW-846. https://www.epa.gov/sites/default/files/2015-12/documents/8265.pdf. August 23, 2022.
EPA. 2009. General definitions. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 413.02. https://www.govinfo.gov/content/pkg/CFR-2009-title40-vol28/pdf/CFR-2009-title40-vol28-sec413-02.pdf. June 30, 2022.
EPA. 2010a. Organic chemicals, plastics, and synthetic fibers. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 414. https://www.govinfo.gov/content/pkg/CFR-2010-title40-vol28/pdf/CFR-2010-title40-vol28-part414.pdf. June 30, 2022.
EPA. 2010b. Specialized definitions. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 433.11. https://www.govinfo.gov/content/pkg/CFR-2010-title40-vol29/pdf/CFR-2010-title40-vol29-sec433-11.pdf. June 30, 2022.
EPA. 2011a. Designation, reportable quantities, and notification. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302. https://www.govinfo.gov/content/pkg/CFR-2011-title40-vol28/pdf/CFR-2011-title40-vol28-part302.pdf. June 30, 2022.
EPA. 2011b. Discarded commercial chemical products, off-specification species, container residues, and spill residues thereof. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.33. https://www.govinfo.gov/content/pkg/CFR-2011-title40-vol26/pdf/CFR-2011-title40-vol26-sec261-33.pdf. June 30, 2022.
EPA. 2011c. Provisional peer-reviewed toxicity values for cis-1,2-dichloroethylene. Cincinnati, OH: U.S. Environmental Protection Agency. EPA690R11020F. https://cfpub.epa.gov/ncea/pprtv/documents/Dichloroethylenecis12.pdf. June 15, 2022.
EPA. 2012a. Criteria and standards for the national pollutant discharge elimination system. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 125. https://www.govinfo.gov/content/pkg/CFR-2012-title40-vol23/pdf/CFR-2012-title40-vol23-part125.pdf. June 30, 2022.
EPA. 2012b. Record of decision: White Chemical Corporation, Newark, Essex County, New Jersey (Operable Unit 3 - Groundwater). U.S. Environmental Protection Agency. https://semspub.epa.gov/work/02/123550.pdf. April 13, 2023.
EPA. 2015. OSWER technical guide for assessing and mitigating the vapor intrusion pathway from subsurface vapor sources to indoor air. U.S. Environmental Protection Agency. OSWER Publication 9200.2–154. https://www.epa.gov/sites/default/files/2015-09/documents/oswer-vapor-intrusion-technical-guide-final.pdf. June 16, 2022.
EPA. 2018a. 2018 Edition of the drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency. EPA822S12001. https://www.epa.gov/system/files/documents/2022-01/dwtable2018.pdf. June 15, 2022.
EPA. 2018b. Compiled AEGL values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2018-08/documents/compiled_aegls_update_27jul2018.pdf. April 12, 2020.
EPA. 2018c. About acute exposure guideline levels (AEGLs). U.S. Environmental Protection Agency. https://www.epa.gov/aegl/about-acute-exposure-guideline-levels-aegls. July 26, 2018.
EPA. 2020a. Final scope of the risk evaluation for trans-1,2-dichloroethylene. U.S. Environmental Protection Agency. EPA740D20007. https://www.epa.gov/sites/default/files/2020-09/documents/casrn_156-60-5_trans-12-dichloroethylene_final_scope.pdf. June 7, 2022.
EPA. 2020b. Provisional peer-reviewed toxicity values for trans-1,2-dichloroethylene (CASRN 156–60-5). Cincinnati, OH: U.S. Environmental Protection Agency. EPA690R20006F. https://cfpub.epa.gov/ncea/pprtv/documents/Dichloroethylenetrans12.pdf. June 15, 2022.
EPA. 2021a. Definitions and general program requirements. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 122. https://www.govinfo.gov/content/pkg/CFR-2021-title40-vol24/pdf/CFR-2021-title40-vol24-sec122-1.pdf. June 30, 2022.
EPA. 2021b. 2017 National Emissions Inventory: January 2021 updated release, technical support document. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA454R21001. https://www.epa.gov/sites/default/files/2021-02/documents/nei2017_tsd_full_jan2021.pdf. June 29, 2022.
EPA. 2022a. Chemical data reporting under the toxic substances control act. U.S. Environmental Protection Agency. https://www.epa.gov/chemical-data-reporting/access-cdr-data. June 13, 2022.
EPA. 2022b. Air quality system data. U.S. Environmental Protection Agency. https://www.epa.gov/outdoor-air-quality-data. June 13, 2022.
EPA. 2022c. Toxic chemical release inventory reporting forms and instructions: Revised 2021 version. U.S. Environmental Protection Agency. EPA740B22002. https://ordspub.epa.gov/ords/guideme_ext/guideme_ext/guideme/file/ry_2021_rfi.pdf. August 22, 2023.
EPA. 2022d. Provisional peer-reviewed toxicity values for cis-1,2-dichloroethylene (cis-1,2-DCE) (CASRN 156–59-2). Cincinnati, OH: U.S. Environmental Protection Agency. EPA690R22001F. https://cfpub.epa.gov/ncea/pprtv/documents/dichloroethylenecis12.pdf. September 13, 2024.
EPA. 2023. National primary drinking water regulations. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141. https://www.govinfo.gov/content/pkg/CFR-2023-title40-vol25/pdf/CFR-2023-title40-vol25-part141.pdf. May 3, 2024.
EPA/AMRL. 1990. The effect of subacute and subchronic oral exposure to cis-1,2-dichloroethylene in rats. Cincinnati, OH: U.S. Environmental Protection Agency. U.S. Air Force Aerospace Medial Research Laboratory. https://ordspub.epa.gov/ords/eims/eimscomm.getfile?p_download_id=491529. August 23, 2022.
Fain JE, Brakefield LA, Sherman L, 1987. Environmental risk management of land treatment operational units. Hazard Waste Hazard Mater 4:83–97. 10.1089/hwm.1987.4.83.
FDA. 2022. Analytical results of the Total Diet Study. U.S. Food and Drug Administration. https://www.fda.gov/food/total-diet-study/analytical-results-total-diet-study. June 13, 2022.
FDA. 2023a. Indirect food additives: adhesives and components of coatings. Subpart B - Substances for use only as components of adhesives. Food and Drug Administration. Code of Federal Regulations. 21 CFR 175.105. https://www.govinfo.gov/content/pkg/CFR-2023-title21-vol3/pdf/CFR-2023-title21-vol3-sec175-105.pdf. September 13, 2024.
FDA. 2023b. Subpart B - Requirements for specific standardized beverages. Bottled water. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 165.110. https://www.govinfo.gov/content/pkg/CFR-2023-title21-vol2/pdf/CFR-2023-title21-vol2-sec165-110.pdf. May 3, 2024.
FDA. 2024. Substances added to food. U.S. Food and Drug Administration. https://www.cfsanappsexternal.fda.gov/scripts/fdcc/?set=FoodSubstances. September 13, 2024.
Feiler HD, Starch PJ, Southworth R. 1980. Organics in municipal sludges survey of forty cities. In: Proceedings of the national conference on municipal industrial sludge utility disposal. Washington, DC: American Society of Civil Engineers, U.S. Environmental Protection Agency, 53–57.
Filser JG, Bolt HM. 1979. Pharmacokinetics of halogenated ethylenes in rats. Arch Toxicol 42(2):123–136. 10.1007/BF00316492.485853
Fogel MM, Taddeo AR, Fogel S. 1986. Biodegradation of chlorinated ethenes by a methane-utilizing mixed culture. Appl Environ Microbial 51:720–724. 10.1128/aem.51.4.720-724.1986.
Frantik E, Hornychova M, Horvath M. 1994. Relative acute neurotoxicity of solvents: isoeffective air concentrations of 48 compounds evaluated in rats and mice. Environ Res 66(2):173–185. 10.1006/enrs.1994.1053.8055839
Freundt KJ, Macholz J. 1978. Inhibition of mixed function oxidases in rat liver by trans- and cis-1,2-dichloroethylene. Toxicology 10:131–139. 10.1016/0300-483X(78)90063-X.684758
Freundt KJ, Liebaldt GP, Lieberwirth E. 1977. Toxicity studies on trans-1,2-dichloroethylene. Toxicology 7(2):141–153. 10.1016/0300-483X(77)90059-2.854930
Fusillo TV, Hochreiter JJ, Lord DG. 1985. Distribution of volatile organic compounds in a New Jersey coastal plain aquifer system. Ground Water 23:354–360. 10.1111/j.1745-6584.1985.tb00780.x.
Galli A, Bauer C, Bronzetti G, 1982. [Genetic activity of 1,2-dichloroethylene A. In vitro studies]. Boll Sot Ital Biol Sper 58:860–863. (Italian)
Gargas ML, Seybold PG, Andersen ME. 1988. Modeling the tissue solubilities and metabolic rate constant (Vmax) of halogenated methanes, ethanes, and ethylenes. Toxicol Lett 43(1–3):235–256. 10.1016/0378-4274(88)90031-8.3176068
Gargas ML, Burgess RJ, Voisard DE, 1989. Partition coefficients of low-molecular-weight volatile chemicals in various liquids and tissues. Toxicol Appl Pharmacol 98(1):87–99. 10.1016/0041-008X(89)90137-3.2929023
Ghassemi M, Qunilivan S, Bachmaier J. 1984. Characteristics of leachates from hazardous waste landfills. J Environ Sci Health A Environ Sci Eng 19(5):579–620. 10.1080/10934528409375180.
Goodenkauf O, Atkinson JC. 1986. Occurrence of volatile organic chemicals in Nebraska groundwater. Ground Water 24(2):231–233. 10.1111/j.1745-6584.1986.tb00999.x.
Goodman MA, Tuazon EC, Atkinson R, 1986. A study of the atmospheric reactions of chloroethanes with OH radicals. In: ACS Division of Environmental Chemistry 192nd national meeting. American Chemical Society, 169–171.
Gosselin RE, Smith RP, Hodge HC. 1984. 1,2-Dichloroethene. In: Clinical toxicology of commercial products. 5th ed. Baltimore, MD: Williams and Wilkins, 16.
Gossett JM. 1987. Measurement of Henry’s Law constant for C1 and C2 chlorinated hydrocarbons. Environ Sci Technol 21:202–206. 10.1021/es00156a012.
Gossett RW, Brown DA, Young DR. 1983. Predicting the bioaccumulation of organic compounds in marine organisms using octanol/water partition coefficients. Mar Pollut Bull 14:387–392. 10.1016/0025-326X(83)90604-5.
Gradiski D, Bonnet P, Raoult G, 1978. Comparative acute inhalation toxicity of the principal chlorinated aliphatic solvents. Arch Mal Prof Med Travail Secur Soc 39(4–5):249–257. (French)
Granstrom ML, Ahlert RC, Wiesenfeld J. 1984. The relationships between the pollutants in the sediments and in the water of the Delaware and Raritan Canal. Water Sci Technol 16:375–380. 10.2166/wst.1984.0144.
Greim H, Bonse G, Radwan Z, 1975. Mutagenicity in vitro and potential carcinogenicity of chlorinated ethylenes as a function of metabolic oxirane formation. Biochem Pharmacol 224:2013–2017. 10.1016/0006-2952(75)90396-2
Grimsrud EP, Rasmussen RA. 1975. Survey and analysis of halocarbons in the atmosphere by gas chromatography-mass spectrometry. Atmos Environ 9:1014–1017. 10.1016/0004-6981(75)90022-0.
Gürtler RR, Moeller U, Sommer S, 1994. Photooxidation of exhaust pollutants: III. Photooxidation of the chloroethenes: Degradation efficiencies, quantum yields and products. Chemosphere 29(8):1671–1682. 10.1016/0045-6535(94)90314-X.
Hall LW, Hall WS, Bushong SJ, 1987. In-situ striped bass (Morone saxatilis) contaminant and water quality studies in the Potomac River. Aquat Toxicol 10:73–99. 10.1016/0166-445X(87)90016-6.
Hall LC, Mallon B, Hsieh P, 1989. Health risk assessment of trans-1,2-dichloroethylene in California drinking water. Livermore, CA: University of California. DE89007229. UCRL-21062. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/DE89007229.xhtml. June 30, 2022.
Hallen RT, Pyne JW, Molton PM. 1986. Transformation of chlorinated ethenes and ethanes by anaerobic microorganisms. In: ACS Division of Environmental Chemistry 192^nd^ national meeting. American Chemical Society, 344–346.
Hamilton A. 1934. 1,2-Dichloroethene. In: Industrial toxicology. New York, NY: Harper and Brothers Publishers, 217–218.
Hand DW, Crittenden JC, Gehin JL, 1986. Design and evaluation of an air stripping tower for removing VOCs from groundwater. J Am Water Works Assoc 78(9):87–97. 10.1002/j.1551-8833.1986.tb05815.x.
Hanioka N, Jinno H, Nishimura T, 1998. Changes in hepatic cytochrome P450 enzymes by cis-and trans-1,2-dichloroethylenes in rat. Xenobiotica 28(1):41–51. 10.1080/004982598239740.9493318
Harjumäki R, Pridgeon CS, Ingelman-Sundberg M. 2021. CYP2E1 in alcoholic and non-alcoholic liver injury. Roles of ROS, reactive intermediates and lipid overload. Int J Mol Sci 22(15):8221. 10.3390/ijms22158221.34360999
Hawley GG. 1981. 1,2-Dichloroethene. In: The condensed chemical dictionary. 10^th^ ed. New York, NY: Van Nostrand Reinhold Co., 33.
Hayes JR, Condie LW, Egle JL, 1987. The acute and subchronic toxicity in rats of trans-1,2-dichloroethylene in drinking water. J Am Coll Toxicol 6(4):471–478. 10.3109/10915818709075692.
Hopkins GD, McCarty PL. 1995. Field evaluation of in situ aerobic cometabolism of trichlorethylene and three dichloroethylene isomers using phenol and toluene as the primary substrates. Environ Sci Technol 29(6):1628–1637. 10.1021/es00006a029.22276888
Horvath AL. 1982. 1,2-Dichloroethene. In: Halogenated hydrocarbons solubility - miscibility with water. New York, NY: Marcel Dekker Inc., 496–497.
Hsu CY, Chiang HC, Shie RH, 2018. Ambient VOCs in residential areas near a large-scale petrochemical complex: Spatiotemporal variation, source apportionment and health risk. Environ Pollut 240:95–104. 10.1016/j.envpol.2018.04.076.29730422
Hurtt ME, Valentine R, Alvarez L. 1993. Developmental toxicity of inhaled trans-1,2-dichloroethylene in the rat. Fundam Appl Toxicol 20(2):225–230. 10.1006/faat.1993.1030.8449394
IARC. 2024. Agents classified by the IARC monographs. International Agency for Research on Cancer. https://monographs.iarc.fr/list-of-classifications. September 13, 2024.
Illinois ENR. 1984. Investigation of a volatile organic chemical plume in Northern Winnebago County, Illinois. Springfield, IL: Illinois Department of Energy and Natural Resources. PB85114452. ILENRRE8409. https://www.ideals.illinois.edu/items/73378. June 30, 2022.
IRIS. 2010a. cis-1,2-Dichloroethylene; CASRN 156–59-2. Integrated Risk Information System. Chemical assessment summary. U.S. Environmental Protection Agency. https://iris.epa.gov/static/pdfs/0418_summary.pdf. October 2, 2017.
IRIS. 2010b. trans-1,2-Dichloroethylene; CASRN 156–60-5. Integrated Risk Information System. Chemical assessment summary. U.S. Environmental Protection Agency. https://iris.epa.gov/static/pdfs/0314_summary.pdf. October 2, 2017.
Janssen DB, Grobben G, Hoekstra R, 1988. Degradation of trans-1,2-dichloroethene in mixed and pure cultures of methanotrophic bacteria. Appl Microbial Biotechnol 29:392–399. 10.1007/BF00265825.
Jeffers PM, Ward LM, Woytowitch LM, 1989. Homogenous hydrolysis rate constants for selected chlorinated methanes, ethanes, ethenes, and propanes. Environ Sci Technol 23:965–969. 10.1021/es00066a006.
Ji G, Xu C, Sun H, 2016. Organochloride pesticides induced hepatic ABCG5/G8 expression and lipogenesis in Chinese patients with gallstone disease. Oncotarget 7(23):33689–33702. 10.18632/oncotarget.9399.27203212
Kallman MJ, Lynch MR, Landauer MR. 1983. Taste aversions to several halogenated hydrocarbons. Neurobehav Toxicol Teratol 5(1):23–27.6856006
Kastner M. 1991. Reductive dechlorination of tri- and tetrachloroethylenes depends on transition from aerobic to anaerobic conditions. Appl Environ Microbiol 57(7):2039–2046. 10.1128/aem.57.7.2039-2046.1991.1892393
Kawamura K, Kaplan IR. 1983. Organic compounds in the rainwater of Los Angeles. Environ Sci Technol 17(8):497–501. 10.1021/es00114a011.22283170
Kernan GJ, Ji BT, Dosemeci M, 1999. Occupational risk factors for pancreatic cancer: a case-control study based on death certificates from 24 U.S. states. Am J Ind Med 36(2):260–270. 10.1002/(sici)1097-0274(199908)36:2<260::aid-ajim5>3.0.co;2-p.10398934
Klier NJ, West RJ, Donberg PA. 1999. Aerobic biodegradation of dichloroethylenes in surface and subsurface soils. Chemosphere 38(5):1175–1188. 10.1016/S0045-6535(98)00485-8.10028665
Koch R, Schlegelmilch R, Wolf HU. 1988. Genetic effects of chlorinated ethylenes in the yeast Saccharomyces cerevisiae. Mutat Res 206(2):209–216. 10.1016/0165-1218(88)90162-0.3050501
Kolpin DW, Squillace PJ, Zogorski JS, 1997. Pesticides and volatile organic compounds in shallow urban groundwater of the United States. In: Chilton D, ed. Groundwater in the urban environment. A.A. Balkema, 469–474.
Krill RM, Sonzogni WC. 1986. Chemical monitoring of Wisconsin’s groundwater. J Am Water Works Assoc 78(9):70–75. 10.1002/j.1551-8833.1986.tb05812.x.
Ladics GS. 2007. Use of SRBC antibody responses for immunotoxicity testing. Methods 41(1):9–19. 10.1016/j.ymeth.2006.07.020.17161298
Lam RHF, Brown JP, Fan AM, 1994. Chemicals in California drinking water source contaminants risk assessment, risk management, and regulatory standards. J Hazard Mater 39(2):173–192. 10.1016/0304-3894(94)00053-0.
Lao RC, Thomas RS, Bastien P, 1982. Analysis of organic priority pollutants and non-priority pollutants in environmental samples by GC/MS computer systems. In: Albaiges J, ed. Analytical techniques in environmental chemistry II. New York, NY: Pergamon Press LTD, 107–118.
LaRegina J, Bozzelli JW, Harkov R, 1986. Volatile organic compounds at hazardous waste sites and a sanitary landfill in New Jersey. An up-to-date review of the present situation. Environ Prog 5(1):18–27. 10.1002/ep.670050109.
Lee MD, Thomas JM, Borden RC, 1988. Biorestoration of aquifers contaminated with organic compounds. CRC Crit Rev Environ Control 18(1):29–89. 10.1080/10643388809388342.
Lehmann KB, Schmidt-Kehl L. 1936. [The thirteen most important chlorinated aliphatic hydrocarbons from the standpoint of industrial hygiene]. Arch Hyg 116:132–268. (German)
Leibman KC, Ortiz E. 1977. Metabolism of halogenated ethylenes. Environ Health Perspect 21:91–97. 10.1289/ehp.772191.612463
Lesage S, Jackson RE, Priddle MW, 1990. Occurrence and fate of organic solvent residues in anoxic groundwater at the Gloucester Landfill, Canada. Environ Sci Technol 24(4):559–566. 10.1021/es00074a016.
Leschber R, Mergler-Voelkl R, Nerger M. 1990. Soil and groundwater contamination by low boiling chlorinated hydrocarbons in Berlin. Formation of metabolites and their analytical determination. Int J Environ Anal Chem 39(2):159–164. 10.1080/03067319008027692.
Lilly PD, Thornton-Manning JR, Gargas ML, 1998. Kinetic characterization of CYP2E1 inhibition in vivo and in vitro by the chloroethylenes. Arch Toxicol 72(10):609–621. 10.1007/s002040050551.9851676
Lipscomb JC, Garrett CM, Snawder JE. 1997. Cytochrome P450-dependent metabolism of trichloroethylene: interindividual differences in humans. Toxicol Appl Pharmacol 142(2):311–318. 10.1006/taap.1996.8040.9070354
Lipsky D, Jacot B. 1985. Hazardous emissions from sanitary landfills. In: Proceedings of 78th annual meeting of the Air Pollution Control Association, June 16–21. Detroit, MI: Air Pollution Control Association, 1–13.
Lue-Hing C, Lordi DT, Kelada NP. 1981. Fate of priority pollutants in large municipal treatment plants. AIChE Symp Ser 77(209):144–150.
Lyman WJ. 1982. Adsorption coefficient for soils and sediments. In: Lyman WJ, Reehl WF, Rosenblatt DH, eds. Handbook of chemical property estimation methods. New York, NY: McGraw Hill Book Co., 4.1–4.33.
Marshall KA, Pottenger LH. 2016. Chlorocarbons and chlorohydrocarbons. In: Kirk-Othmer encyclopedia of chemical technology. New York, NY: John Wiley and Sons, Inc., 10.1002/0471238961.1921182218050504.a01.pub3.
McCauley PT, Robinson M, Daniel FB, 1995. The effects of subacute and subchronic oral exposure to cis-1,2-dichloroethylene in Sprague-Dawley rats. Drug Chem Toxicol 18(2–3):171–184. 10.3109/01480549509014319.7497910
McMillan DA. 1986. Toxicity of the cis and trans isomers of 1,2-dichloroethylene. Partial fulfillment of requirements for the degree of Doctor of Philosophy. Pharmaceutical Sciences. Omaha, NE: University of Nebraska
Michal J. 1976. Toxicity of pyrolysis and combustion products of poly-(vinyl chloride). Fire Mater 1:57–62. 10.1002/fam.810010205.
Milde G, Nerger M, Mergler R. 1988. Biological degradation of volatile chlorinated hydrocarbons in groundwater. Water Sci Technol 20(3):67–73. 10.2166/wst.1988.0083.
Mortelmans K, Haworth S, Lawlor T, 1986. Salmonella mutagenicity tests: II. Results from the testing of 270 chemicals. Environ Mutagen 8(Suppl 7):1–119. 10.1002/em.2860080703.
Mudder TI. 1981. Development of empirical structure-biodegradability relationships and testing protocol for slightly soluble and volatile priority pollutants. Ann Arbor, MI: University Microfilms International.
Mudder TI, Musterman JL. 1982. Development of empirical structure biodegradability relationships and biodegradability testing protocol for volatile and slightly soluble priority pollutants. In: Division of Environmental Chemistry of the American Chemical Society. Kansas City, MO: American Chemical Society, 52–53.
Mumtaz MM, Ray M, Crowell SR, 2012a. Translational research to develop a human PBPK models tool kit-volatile organic compounds (VOCs). J Toxicol Environ Health A 75(1):6–24. 10.1080/15287394.2012.625546.22047160
Mumtaz M, Fisher J, Blount B, 2012b. Application of physiologically based pharmacokinetic models in chemical risk assessment. J Toxicol 2012:904603. 10.1155/2012/904603.22523493
Munson AE, Sanders VM, Douglas KA, 1982. In vivo assessment of immunotoxicity. Environ Health Perspect 43:41–52. 10.1289/ehp.824341.7060547
Myers VB. 1983. Remedial activities at the Miami Drum Site, Florida. In: National conference on management of uncontrolled hazardous waste sites. Silver Springs, MD: Hazardous Materials Control Research Institute, 354–357.
Nakahama T, Sarutani S, Inouye Y. 2000. Effects of chlorinated ethylenes on expression of rat CYP forms: Comparative study on correlation between biological activities and chemical structures. J Health Sci 46:251–258. 10.1248/jhs.46.251.
NAS/NRC. 2006. Human biomonitoring for environmental chemicals. Washington, DC: The National Academies Press, National Research Council. 10.17226/11700.
Naylor LM, Loehr RC. 1982. Priority pollutants in municipal sewage sludge. Biocycle 23:18–22.
Nicola RM, Branchflower R, Pierce D. 1987. Chemical contaminants in bottomfish. J Environ Health 49(6):342–347.
NIOSH. 2019. 1,2-Dichloroethylene. NIOSH pocket guide to chemical hazards. National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgd0195.html. June 15, 2022.
NLM. 2022a. PubChem compound summary: cis-1,2-dichloroethylene. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/643833. August 24, 2022.
NLM. 2022b. PubChem compound summary: trans-1,2-dichloroethylene. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/638186. August 24, 2022.
NOAA. 1980. Quantitation of pollutants in suspended matter and water from Puget Sound. Richland, WA: National Oceanic and Atmospheric Administration. NOAA-80061003. https://repository.library.noaa.gov/view/noaa/11196. October 18, 2022.
NTP. 2002. NTP Technical report on the toxicity studies of trans-1,2-dichloroethylene (CAS No. 156–60-5) administered in microcapsules in feed to F344/N rats and B6C3F1 mice. National Toxicology Program. PB2002108967. NTP Tox 55. https://ntp.niehs.nih.gov/ntp/htdocs/st_rpts/tox055.pdf. October 18, 2022.
NTP. 2013. Draft OHAT approach for systematic review and evidence integration for literature-based health assessments - February 2013. National Toxicology Program. https://ntp.niehs.nih.gov/ntp/ohat/evaluationprocess/draftohatapproach_february2013.pdf. June 30, 2022.
NTP. 2015. OHAT risk of bias rating tool for human and animal studies. National Toxicology Program. https://ntp.niehs.nih.gov/ntp/ohat/pubs/riskofbiastool_508.pdf. March 19, 2019.
NTP. 2021. CASRN index. Report on carcinogens. National Toxicology Program. https://ntp.niehs.nih.gov/pubhealth/roc/index-1.html#P. January 10, 2022.
NTP. 2024. Chemical effects in biological systems (CEBS): cis-1,2-Dichloroethylene (156–59-2). Research Triangle Park, NC: National Toxicology Program. 10.22427/NTP-DATA-DTXSID2024030.
OECD. 2011. Emission scenario document on the chemical industry. Series on Emission Scenario Documents: No. 30. Paris, France: Organisation for Economic Co-operation and Development. ENV/JM/MONO(2011)49. https://www.oecd.org/env/ehs/risk-assessment/48774702.pdf. June 7, 2022.
OECD. 2015. Emission scenario document (ESD) on the use of adhesives. Series on Emission Scenario Documents: No. 34. Paris, France: Organisation for Economic Co-operation and Development. ENV/JM/MONO(2015)4. https://www.oecd.org/officialdocuments/publicdisplaydocumentpdf/?cote=ENV/JM/MONO(2015)4 &doclanguage=en. June 7, 2022.
OSHA. 2023a. Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z-2. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. https://www.govinfo.gov/content/pkg/CFR-2023-title29-vol6/pdf/CFR-2023-title29-vol6-sec1910-1000.pdf. September 13, 2024.
OSHA. 2023b. Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. https://www.govinfo.gov/content/pkg/CFR-2023-title29-vol7/pdf/CFR-2023-title29-vol7-sec1915-1000.pdf. September 13, 2024.
OSHA. 2023c. Safety and health regulations for construction. Subpart D - Occupational health and environment controls. Gases, vapors, fumes, dusts, and mists. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55. https://www.govinfo.gov/content/pkg/CFR-2023-title29-vol8/pdf/CFR-2023-title29-vol8-sec1926-55.pdf. September 13, 2024.
Otson R. 1987. Purgeable organics in Great Lakes raw and treated water. Int J Environ Anal Chem 31(1):41–53. 10.1080/03067318708077128.
Otson R, Williams DT, Bothwell PD. 1982. Volatile organic compounds in water at thirty Canadian potable water treatment facilities. J Assoc Off Anal Chem 65(6):1370–1374. 10.1093/jaoac/65.6.1370.
Page GW. 1981. Comparison of groundwater and surface water for patterns and levels of contamination by toxic substances. Environ Sci Technol 15(12):1475–1481. 10.1021/es00094a008.
Paolini M, Mesirca R, Pozzetti L, 1992. Selective induction of murine liver cytochrome P450 IIB1 by halogenated hydrocarbons. Toxicol Environ Chem 36(3–4):235–249. 10.1080/02772249209357846.
Parsons F, Wood PR, DeMarco J. 1984. Transformations of tetrachloroethene and trichloroethane in microcosms and groundwater. J Am Water Works Assoc 76(2):56–59. 10.1002/j.1551-8833.1984.tb05282.x.
Peyret T, Krishnan K. 2012. Quantitative property-property relationship for screening-level prediction of intrinsic clearance of volatile organic chemicals in rats and its integration within PBPK models to predict inhalation pharmacokinetics in humans. J Toxicol 2012:286079. 10.1155/2012/286079.22685458
Pleil JD, Lindstrom AB. 1997. Exhaled human breath measurement method for assessing exposure to halogenated volatile organic compounds. Clin Chem 43(5):723–730. 10.1093/clinchem/43.5.723.9166222
Plumb RH. 1987. A comparison of ground water monitoring data from CERCLA and RCRA sites. Ground Water Monit Remediat 7:94–100. 10.1111/j.1745-6592.1987.tb00968.x.
Pratt GC, Palmer K, Wu CY, 2000. An assessment of air toxics in Minnesota. Environ Health Perspect 108(9):815–825. 10.1289/ehp.00108815.11017885
Rannug A, Alexandrie AK, Persson I, 1995. Genetic polymorphism of cytochromes P450 1A1, 2D6 and 2E1: regulation and toxicological significance. J Occup Environ Med 37(1):25–36. 10.1097/00043764-199501000-00005.7620940
RePORTER. 2024. 1,2-Dichloroethene. National Institutes of Health, Research Portfolio Online Reporting Tools. https://reporter.nih.gov/. June 24, 2022.
Rooney AA, Boyles AL, Wolfe MS, 2014. Systematic review and evidence integration for literature-based environmental health science assessments. Environ Health Perspect 122(7):711–718. 10.1289/ehp.1307972.24755067
Ruckart PZ, Bove FJ, Maslia M. 2013. Evaluation of exposure to contaminated drinking water and specific birth defects and childhood cancers at Marine Corps Base Camp Lejeune, North Carolina: a case-control study. Environ Health 12:104. 10.1186/1476-069x-12-104.24304547
Ruckart PZ, Bove FJ, Shanley E, 2015. Evaluation of contaminated drinking water and male breast cancer at Marine Corps Base Camp Lejeune, North Carolina: a case control study. Environ Health 14:74. 10.1186/s12940-015-0061-4.26376727
Ruiz P, Ray M, Fisher J, 2011. Development of a human Physiologically Based Pharmacokinetic (PBPK) Toolkit for environmental pollutants. Int J Mol Sci 12(11):7469–7480. 10.3390/ijms12117469.22174611
Sabel G, Clark T. 1984. Volatile organic compounds as indicators of municipal solid waste leachate contamination. Waste Manage Res 2(2):119–130. 10.1016/0734-242x(84)90135-6.
Sabljic A. 1984. Predictions of the nature and strength of soil sorption of organic pollutants by molecular topology. J Agric Food Chem 32(2):243–246. 10.1021/jf00122a016.
Sanhueza E, Heicklen J. 1975a. Reaction of atomic oxygen (3P) with CCl2CH2. J Photochem 4:1–15. 10.1016/0047-2670(75)80010-4.
Sanhueza E, Heicklen J. 1975b. Oxidation of cis- and trans-CHClCHCl. Int J Chem Kinet 7:589–604. 10.1002/kin.550070409.
Sanzgiri UY, Bruckner JV. 1997. Effect of Emulphor, an emulsifier, on the pharmacokinetics and hepatotoxicity of oral carbon tetrachloride in the rat. Fundam Appl Toxicol 36(1):54–61. 10.1006/faat.1997.2290.9073467
Sato A, Nakajima T. 1979. A structure-activity relationship of some chlorinated hydrocarbons. Arch Environ Health 34(2):69–75. 10.1080/00039896.1979.10667371.434934
Sawada M, Sofuni T, Ishidate M. 1987. Cytogenetic studies on 1,1-dichloroethylene and its two isomers in mammalian cells in vitro and in vivo. Mutat Res 187(3):157–163. 10.1016/0165-1218(87)90083-8.3821769
Semprini L. 1995. In situ bioremediation of chlorinated solvents. Environ Health Perspect 103(Suppl 5):101–105. 10.1289/ehp.95103s4101.8565895
Shah JJ, Singh HB. 1988. Distribution of volatile organic chemicals in outdoor and indoor air: a national VOCs data base. Environ Sci Technol 22(12):1381–1388. 10.1021/es00177a001.22200458
Shen TT. 1982b. Air quality assessment for land disposal of industrial wastes. Environ Manage 6:297–305. 10.1007/BF01875061.
Shopp GM, Sanders VM, White KL, 1985. Humoral and cell-mediated immune status of mice exposed to trans-1,2-dichloroethylene. Drug Chem Toxicol 8(5):393–407. 10.3109/01480548509041066.4064950
Silka LR, Wallen DA. 1988. Observed rates of biotransformation of chlorinated aliphatics in groundwater. In: Superfund '88, proceedings of the 9th national conference. Washington, DC: Hazardous Materials Control Research Institute, 138–141.
Singh UP, Orban JE. 1987. The Biscayne Aquifer contamination: cleanup and prevention. Water Resour Bull 23(5):879–888. 10.1111/j.1752-1688.1987.tb02966.x.
Smith JA. 1988. Vapor distribution of trichloroethane and related compounds in soil gas above contaminated groundwater at Picatinny Arsenal, New Jersey. Preprints. In: ACS Division of Environmental Chemistry 196th national meeting. American Chemical Society, 376–377.
Smith LR, Dragun J. 1984. Degradation of volatile chlorinated aliphatic priority pollutants in groundwater. Environ Int 10:291–298. 10.1016/0160-4120(84)90134-X.
Snider EH, Manning FS. 1982. A survey of pollutant emission levels in wastewater and residuals from the petroleum refining industry. Environ Int 7:237–258. 10.1016/0160-4120(82)90114-3.
Staples CA, Werner A, Hoogheem T. 1985. Assessment of priority pollutant concentrations in the United States using STORET database. Environ Toxicol Chem 4:31–42. 10.1002/etc.5620040202.
Stenzel M, Gupta US. 1985. Treatment of contaminated groundwaters with granular activated carbon and air stripping. J Air Pollut Control Assoc 35(12):1304–1309. 10.1080/00022470.1985.10466035.
Stevens VL. 1979. 1,2-Dichloroethylene. In: Grayson M, Eckroth D, eds. Kirk-Othmer encyclopedia of chemical technology. Vol. 5. 3rd ed. New York, NY: John Wiley and Sons, 742–745.
Stonebraker RD, Smith AJ. 1980. Containment and treatment of a mixed chemical discharge from the "Valley of the Drum” near Louisville, Kentucky. In: Control of hazardous material spills proceedings of the 1980 national conference on control of hazardous material spills, May 13–15, 1980, Louisville, Kentucky. Louisville, KY: Vanderbilt University, 1–10.
Suffet IH, Brenner L, Cairo PR. 1980. Gas chromatography-mass spectrometry identification of trace organics in Philadelphia, Pennsylvania, USA drinking waters during a two year period. Water Res 14:853–857.
Swann RL, Laskowski DA, McCall PJ, 1983. A rapid method for the estimation of the environmental parameters octanol/water partition coefficient, soil sorption constant, water to air ratio and water solubility. Res Rev 85:17–28. 10.1007/978-1-4612-5462-1_3.
Sweeney LM, Gearhart JM. 2020. Examples of physiologically based pharmacokinetic modeling applied to risk assessment. In: Fisher JW, Gearhart JM, Lin Z, eds. Physiologically based pharmacokinetic (PBPK) modeling. Academic Press: 281–299. 10.1016/B978-0-12-818596-4.00011-4.
Tabak HH, Quave SA, Mashni CI, 1981. Biodegradability studies with organic priority pollutant compounds. J Water Pollut Control Fed 53:1503–1518.
Tafazoli M, Kirsch-Volders M. 1996. In vitro mutagenicity and genotoxicity study of 1,2-dichloroethylene, 1,1,2-trichloroethane, 1,3-dichloropropane, 1,2,3-trichloropropane and 1,1,3-trichloropropene, using the micronucleus test and the alkaline single cell gel electrophoresis technique (comet assay) in human lymphocytes. Mutat Res 371(3–4):185–202. 10.1016/s0165-1218(96)90107-x.9008720
Tan YM, Chan M, Chukwudebe A, 2020. PBPK model reporting template for chemical risk assessment applications. Regul Toxicol Pharmacol 115:104691. 10.1016/j.yrtph.2020.104691.32502513
Tandoi V, Distefano TD, Bowser PA, 1994. Reductive dehalogenation of chlorinated ethenes and halogenated ethanes by a high-rate anaerobic enrichment culture. Environ Sci Technol 28(5):973–979. 10.1021/es00054a033.22191843
Thomas RG. 1982. Volatilization from water. In: Lyman WJ, Reehl WF, Rosenblatt DH, eds. Handbook of chemical property estimation methods. New York, NY: McGraw Hill Book Co., 15.11–15.34.
TRI23. 2025. 1,2-Dichloroethene. TRI search. Washington, DC: U.S. Environmental Protection Agency. https://www.epa.gov/enviro/tri-search. February 11, 2025.
Tuazon EC, Atkinson R, Winer AM, 1984. A study of the atmospheric reaction of 1,3-dichloropropene and other selected organochlorine compounds. Arch Environ Contam Toxicol 13:691–700. 10.1007/BF01055932.
Tuazon EC, Atkinson R, Aschmann SM, 1988. Atmospheric reactions of chloroethenes with the OH radical. Int J Chem Kinet 20:241–265. 10.1002/kin.550200305.
U.S. Army. 1994. Concentration stability of four volatile organic compounds in soil subsamples. U.S. Army Corps of Engineers. ADA280124. Special Report 94–6. https://apps.dtic.mil/sti/pdfs/ADA280124.pdf. August 23, 2022.
U.S. Army. 2018. Long-term monitoring report: CCFTBR0039 (Site 39) Former oil water separator 2–1251: October 2017 Sampling event: Fort Bragg, North Carolina. U.S. Army Corps of Engineers. https://edocs.deq.nc.gov/WasteManagement/DocView.aspx?id=1482295&dbid=0&repo=WasteManagement. June 7, 2022.
USGS. 2006. Volatile organic compounds in the Nation's ground water and drinking-water supply wells. Reston, VA: U.S. Geological Survey. Circular 1292. https://pubs.usgs.gov/circ/circ1292/. May 13, 2022.
Vannelli T, Logan M, Arciero DM, 1990. Degradation of halogenated aliphatic compounds by the ammonia-oxidizing bacterium Nitrosomonas europaea. Appl Environ Microbiol 56(4):1169–1171. 10.1128/aem.56.4.1169-1171.1990.2339874
Veith GD, Kosian P. 1983. Estimating bioconcentration potential from octanol/water partition coefficients. In: MacKay D, ed. Physical behavior of PCBs in the Great Lakes. Ann Arbor, MI: Ann Arbor Science Publishers, 269–282.
Vogel TM, Criddle CS, McCarty PL. 1987. ES Critical Reviews: Transformations of halogenated aliphatic compounds. Environ Sci Technol 21(8):722–736. 10.1021/es00162a001.19995052
Vogt WG, Walsh JJ. 1985. Volatile organic compounds in gases from landfill simulators. In: 78th Annual meeting of the Air Pollution Control Association. Detroit, MI: Air Pollution Control Association, 17.
Wang T, Lenahan R, Kanik M. 1985b. Impact of trichloroethylene contaminated groundwater discharged to the main canal and Indian River Lagoon, Vero Beach, Florida. Bull Environ Contam Toxicol 34:578–586. 10.1007/BF01609779.3986398
Wang T, Lenahan R, Kanik M, 1985a. The removal of trichloroethylene contaminated groundwater at Vero Beach, Florida. Arch Environ Contam Toxicol 14:719–723. 10.1007/BF01055779.
Wang H, Xiang Z, Wang L, 2018. Emissions of volatile organic compounds (VOCs) from cooking and their speciation: A case study for Shanghai with implications for China. Sci Total Environ 621:1300–1309. 10.1016/j.scitotenv.2017.10.098.29054635
Weast RC. 1983. 1,2-Dichloroethene. In: CRC handbook of chemistry and physics. 72nd ed. Boca Raton, FL: CRC Press, Inc., C295.
Westrick JJ, Mello JW, Thomas RF. 1984. The groundwater supply survey. J Amer Water Works Assoc 76(5):52–59. 10.1002/j.1551-8833.1984.tb05334.x.
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. April 25, 2012.
WHO. 2022. Guidelines for drinking-water quality. Fourth edition incorporating the first and second addenda. World Health Organization. https://www.who.int/publications/i/item/9789240045064. June 22, 2022.
Wilson BH, Smith GB, Rees JF. 1986. Biotransformations of selected alkylbenzenes and halogenated aliphatic hydrocarbons in methanogenic aquifer material: a microcosm study. Environ Sci Technol 20(10):997–1002. 10.1021/es00152a005.22257397
Wisconsin DNR. 1988. Volatile organic compounds in groundwater and leachate at Wisconsin landfills. Madison, WI: Wisconsin Department of Natural Resources. DNR-004a. WR85R018. https://digital.library.wisc.edu/1711.dl/HLPFVKRI2TMVD87. June 30, 2022.
Wisconsin DNR. 1989. VOC contamination at selected Wisconsin landfills-sampling results and policy implications. Madison, WI: Wisconsin Department of Natural Resource. DNR-004b. https://digital.library.wisc.edu/1711.dl/PD2NNXATSJIRR8N. June 30, 2022.
Wolf F, Gorelik L. 1984. Persistence of synthetic solvent contaminants in a glacial outwash aquifer, Washington State. In: 7^th^ Annual Madison waste conference proceedings. Madison, WI: University of Wisconsin, 116–131.
Wood JA, Porter ML. 1987. Hazardous pollutants in class II landfills. JAPCA 37(5):609–615. 10.1080/08940630.1987.10466250.3446753
WQP. 2024. 1,2-Dichloroethene. Water quality portal. Environmental Protection Agency (EPA); National Water Quality Monitoring Council (NWQMC); United States Geological Survey (USGS). https://www.waterqualitydata.us/portal/. September 16, 2024.
Yeh HC, Kastenberg WE. 1991. Health risk assessment of biodegradable volatile organic chemicals: a case study of PCE, TCE, DCE, and VC. J Hazard Mater 27:111–126. 10.1016/0304-3894(91)80024-I.
Zeiger E, Anderson B, Haworth S, 1988. Salmonella mutagenicity tests: IV. Results from the testing of 300 chemicals. Environ Mol Mutagen 11(Suppl 12):1–157. 10.1002/em.2850190603.
Zisook RE, Simmons BD, Vater M, 2020. Emissions associated with operations of four different additive manufacturing or 3D printing technologies. J Occup Environ Hyg 17(10):464–479. 10.1080/15459624.2020.1798012.32809925