# CONTRIBUTORS & REVIEWERS

## CHEMICAL MANAGER TEAM

- Malcolm Williams, D.V.M., Ph.D. (Lead)
  Gaston Casillas, Ph.D.
  Sam Keith, M.S., C.H.P.
  Mike Fay, Ph.D.
- ATSDR, Office of Innovation and Analytics,
  Toxicology Section, Atlanta, GA
- Julie M. Klotzbach, Ph.D.
  Mario Citra, Ph.D.
  Zachariah Guerrette. Ph.D., D.A.B.T.
  Deborah Herber, Ph.D.
  Ramsey Hanna, Ph.D.
- SRC, Inc., North Syracuse, NY

## REVIEWERS

Interagency Minimal Risk Level Workgroup:

- Includes ATSDR; National Center for Environmental Health (NCEH); National Institute for Occupational Safety and Health (NIOSH); U.S. Environmental Protection Agency (EPA); National Toxicology Program (NTP).

Additional reviews for science and/or policy:

- ATSDR, Office of Community Health Hazard Assessment; ATSDR, Office of Capacity Development and Applied Prevention Science; ATSDR, Office of Science; NCEH, Division of Laboratory Sciences; NCEH, Division of Environmental Health Science and Practice; EPA, Office of Research and Development; EPA, Office of Water.

## PEER REVIEWERS

1. Mary Beth Genter, Ph.D.; Professor, Department of Environmental Health; University of Cincinnati; Cincinnati, Ohio; peer-review of Confidential (1999, 2014, 2015a, 2015b, 2015c) studies only.
2. Matt Simcik, Ph.D.; Professor; Division of Environmental Health Sciences; School of Public Health; University of Minnesota; Minneapolis, Minnesota.
3. G.A. Shakeel Ansari, Ph.D.; Professor; Department of Pathology; University of Texas Medical Branch; Galveston, Texas.
4. Andrew J. Gow, MEd, Ph.D.; Professor of Pharmacology & Toxicology; Ernest Mario School of Pharmacy; Rutgers University; Piscataway, New Jersey; peer-review of Confidential (1999, 2014, 2015a, 2015b, 2015c) studies only.
5. Stephen M. Roberts, Ph.D.; Director, Center for Environmental & Human Toxicology; Professor, College of Veterinary Medicine; College of Medicine, and College of Public Health and Health Professions; University of Florida; Gainesville, Florida; peer-review of Confidential (1999, 2014, 2015a, 2015b, 2015c) studies only.

These experts collectively have knowledge of toxicology, chemistry, and/or health effects. All reviewers were selected in conformity with Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

ATSDR scientists review peer reviewers’ comments and determine whether changes will be made to the profile based on comments. The peer reviewers’ comments and responses to these comments are part of the administrative record for this compound.

The listing of peer reviewers should not be understood to imply their approval of the profile's final content. The responsibility for the content of this profile lies with ATSDR.