# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding 1,2-dichloroethene in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for 1,2-dichloroethene.

Table 7-1 Regulations and Guidelines Applicable to 1,2-Dichloroethene

Agency | Description | Information | Reference
Air
EPA | RfC | Information reviewed but value not estimated | IRIS 2010a, 2010b
| Provisional peer-reviewed toxicity values
| cis-1,2-Dichloroethene | | EPA 2022d
| Screening provisional chronic RfC | 4×10^−2^ mg/m^3^ (0.01 ppm)
| Screening provisional subchronic RfC | 4×10–1 mg/m^3^ (0.1 ppm)
| trans-1,2-Dichloroethene | | EPA 2020b
| Screening provisional chronic RfC | 4×10^−2^ mg/m^3^ (0.01 ppm)
| Screening provisional subchronic RfC | 4×10–1 mg/m^3^ (0.1 ppm)
WHO | Air quality guidelines | Not listed | WHO 2010
Water & Food
EPA | Drinking water standards and health advisories | | EPA 2018a
| cis-1,2-Dichloroethene
| 1-Day health advisory (10-kg child) | 4 mg/L
| 10-Day health advisory (10-kg child) | 3 mg/L
| DWEL | 0.07 mg/L
| Lifetime health advisory | 0.01 mg/L
| trans-1,2-Dichloroethene
| 1-Day health advisory (10-kg child) | 20 mg/L
| 10-Day health advisory (10-kg child) | 2 mg/L
| DWEL | 0.7 mg/L
| Lifetime health advisory | 0.1 mg/L
| National primary drinking water regulations | | EPA 2023
| cis-1,2-Dichloroethene
| MCL | 0.07 mg/L
| MCLG | 0.07 mg/L
| trans-1,2-Dichloroethene
| MCL | 0.1 mg/L
| MCLG | 0.1 mg/L
| RfD
| cis-1,2-Dichloroethene | 0.002 mg/kg/day | IRIS 2010a
| trans-1,2-Dichloroethene | 0.02 mg/kg/day | IRIS 2010b
| Provisional peer-reviewed toxicity values | | EPA 2011c
| cis-1,2-Dichloroethene
| Provisional subchronic RfD | 2×10^−2 ^mg/kg/day
WHO | Drinking water quality guidelines | | WHO 2022
| 1,2-Dichloroethene
| guideline value | 0.05 mg/L (50 gg/L)
| TDI | 17 gg/kg body weight
FDA | Substances added to food (formerly EAFUS) | Not listed | FDA 2024
| Indirect food additives regulations | Permitted as a | FDA 2023a
| 1,2-Dichloroethene (mixed isomers) | component of adhesives
| Allowable level in bottled water | | FDA 2023b
| cis-1,2-Dichloroethene | 0.07 mg/L
| tra ns-1,2-Dichloroethene | 0.1 mg/L
Cancer
HHS | Carcinogenicity classification | Not evaluated | NTP 2021
EPA | Carcinogenicity classification | Inadequate information to assess carcinogenic potential | IRIS 2010a, 2010b
IARC | Carcinogenicity classification | Not evaluated | IARC 2024
Occupational
OSHA | PEL (8-hour TWA) for general industry, shipyards and construction | | OSHA 2023a, 2023b, 2023c
| 1,2-Dichloroethene | 200 ppm (790 mg/m^3^)
NIOSH | REL (up to 10-hour TWA) | | NIOSH 2019
| 1,2-Dichloroethene | 200 ppm (790 mg/m^3^)
| IDLH
| 1,2-Dichloroethene | 1,000 ppm
EPA | AEGLs-air | | EPA 2018b
| cis-1,2-Dichloroethene
| AEGL 1^a^
| 10-minute | 140 ppm
| 30-minute | 140 ppm
| 60-minute | 140 ppm
| 4-hour | 140 ppm
| 8-hour | 140 ppm
| AEGL 2^a^
| 10-minute | 500 ppm
| 30-minute | 500 ppm
| 60-minute | 500 ppm
| 4-hour | 340 ppm
| 8-hour | 230 ppm
| AEGL 3^a^
| 10-minute | 850 ppm
| 30-minute | 850 ppm
| 60-minute | 850 ppm
| 4-hour | 620 ppm
| 8-hour | 310 ppm
| trans-1,2-Dichloroethene
| AEGL 1^a^
| 10-minute | 280 ppm
| 30-minute | 280 ppm
| 60-minute | 280 ppm
| 4-hour | 280 ppm
| 8-hour | 280 ppm
| AEGL 2^a^
| 10-minute | 1,000 ppm
| 30-minute | 1,000 ppm
| 60-minute | 1,000 ppm
| 4-hour | 690 ppm
| 8-hour | 450 ppm
| AEGL 3^a^
| 10-minute | 1,700 ppm
| 30-minute | 1,700 ppm
| 60-minute | 1,700 ppm
| 4-hour | 1,200 ppm
| 8-hour | 620 ppm
DOE | PACs-air | | DOE 2024a
| 1,2-Dichloroethene
| PAC-1^b^ | 140 ppm
| PAC-2^b^ | 500 ppm
| PAC-3^b^ | 850 ppm
| cis-1,2-Dichloroethene
| PAC-1^b^ | 140 ppm
| PAC-2^b^ | 500 ppm
| PAC-3^b^ | 850 ppm
| trans-1,2-Dichloroethene
| PAC-1^b^ | 280 ppm
| PAC-2^b^ | 1,000 ppm
| PAC-3^b^ | 1,700 ppm

a Definitions of AEGL terminology are available from U.S. Environmental Protection Agency (EPA 2018c).

b Definitions of PAC terminology are available from U.S. Department of Energy (DOE 2024b).

AEGL = acute exposure guideline level; DOE = Department of Energy; DWEL = drinking water equivalent level; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; MCL = maximum contaminant level; MCLG = maximum contaminant level goal; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TDI = tolerable daily intake; TWA = time- weighted average; WHO = World Health Organization