# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Information regarding the chemical identity of 1,2-dichloroethene is presented in Table 4-1. 1,2-Dichloroethene is also known as 1, 2-dichloroethylene, acetylene dichloride, and 1,2-DCE. The substance is a highly flammable, colorless liquid with a discernable odor (NLM 2022a, 2022b).

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of 1,2-dichloroethene is presented in Table 4-2. There are two geometric isomers of 1,2-dichloroethene: the cis- form and the trans- form. The two are often used as a mixture, which typically contains more trans-1,2-dichloroethene. Both cis- and trans-1,2-dichloroethene are halogenated VOCs and both have vapor densities heavier than air (NLM 2022a, 2022b).

Both isomers have high vapor pressure and Henry’s law constants and have been described as soluble in most organic solvents such as alcohol and ether (NLM 2022a, 2022b).

Table 4-1 Chemical Identity of Isomers of 1,2-Dichloroethene

Characteristic | Information^a^
Chemical name | 1,2-Dichloroethene | cis-1,2-Dichloroethene | trans-1,2-Dichloroethene
Synonym(s) and registered trade name(s) | Acetylene dichloride; 1,2-Dichloroethylene; sym-1,2-Dichloroethylene; 1,2-DCE; Dioform^b^ | (Z)-1,2-Dichloroethene; (Z)-1,2-Dichloroethylene; cis-Acetylene dichloride; cis-1,2-Dichloroethylene; cis-Dichloroethylene | (E)-1,2-Dichloroethene; (E)-1,2-Dichloroethylene; trans-Acetylene dichloride; trans-1,2-Dichloroethylene; trans-Dichloroethylene
Chemical formula | C_2_H_2_Cl_2_ | C_2_H_2_Cl_2_ | C_2_H_2_Cl_2_
SMILES | ClCCCl | ClCCCl | ClCCCl
Chemical structure | [image] | [image] | [image]
CAS Registry Number | 540-59-0 | 156-59-2 | 156-60-5

a All information from NLM (2022a; cis-1,2-dichloroethene) and NLM (2022b; trans-1,2-dichloroethene), except where noted.

b Bennett 1981.

CAS = Chemical Abstracts Services

Table 4-2 Physical and Chemical Properties of cis- and trans-1,2-Dichloroethene^a^

Property | cis-1,2-Dichloroethene | trans-1,2-Dichloroethene | Reference
Molecular weight | 96.95 | 96.95 | NLM 2022a, 2022b
Color | Colorless | Colorless | NLM 2022a, 2022b
Physical state | Liquid | Liquid | Hawley 1981; NLM 2022a, 2022b
Melting point | −80.0°C | −49.8°C | NLM 2022a, 2022b
Boiling point | 58–60°C at 760 mmHg | 47–49°C at 760 mmHg | NLM 2022a, 2022b
Density (g/cm^3^) | 1.2837 | 1.2565 | NLM 2022a, 2022b
Odor | Slightly acrid, chloroform-like odor | Slightly acrid, chloroform-like odor | NLM 2022a, 2022b
Odor threshold:
Water | No data | No data
Air | No data | Odor low: 0.3357 mg/m^3^; odor high 1,975.00 ppm | NLM 2022b
Taste threshold | No data | No data
Solubility:
Water (at 25°C) | 6,410 mg/L at 25°C | 4,520 mg/L at 25°C | NLM 2022b
Organic solvents | Soluble in ether, alcohol, benzene, acetone, chloroform | Soluble in ether, alcohol, benzene, acetone, chloroform | Weast 1983
Partition coefficients:
Log K_ow_ | 1.86 | 2.09 (recommended value); 2.06 | NLM 2022a, 2022b
Log K_oc_ | 1.69 (estimated) | 1.56 (estimated) | NLM 2022a, 2022b
Vapor pressure | 200 mmHg at 25°C | 265 mmHg at 20°C; 395 mmHg; 410 mmHg at 30°C | Stevens 1979; NLM 2022a, 2022b
Henry’s law constant at 24.8°C | 4.86×10^−3^ atm-m^3^/mol | 8.30×10^−3^ atm-m^3^/mol | ATSDR 2022b
Autoignition temperature | 460°C | 460°C | NLM 2022a, 2022b
Flashpoint | 2°C; 6°C; | 2°C | NLM 2022a, 2022b
Flammability limits | Class IB Flammable Liquid: flash point <73°F and boiling point ≥ 100°F | Class IB Flammable Liquid: flash point <73°F and boiling point ≥ 100°F | NLM 2022a, 2022b
Conversion factors in air at 25°C | 1 ppm (v/v)=3.96 mg/m^3^; 1 mg/m^3^=0.25 ppm (v/v) | 1 ppm (v/v)=3.96 mg/m^3 ^; 1 mg/m^3^=0.25 ppm (v/v)
Explosive limits | 5.6–12.8% in air | 9.7–12.8% in air | NLM 2022a, 2022b

a All information from NLM (2022a; cis-1,2-dichloroethene) and NLM (2022b; trans-1,2-dichloroethene), except where noted.