# CHAPTER 1 RELEVANCE TO PUBLIC HEALTH

## 1.1 OVERVIEW AND U.S. EXPOSURES

1,2-Dichloroethene is a man-made, halogenated, volatile, low molecular weight liquid with a sweet smell. It is used as a chemical intermediate or an industrial solvent. Although 1,2-dichloroethene is often referred to as a single chemical, it exists as two geometric isomers (e.g., cis- and trans-1,2-dichloroethene) that have distinct properties.

1,2-Dichloroethene tends to volatilize from environmental media to air where the dominant removal process is a reaction with photochemically generated oxygenated species (e.g., hydroxyl radicals) to form formyl chloride. Other reactions with ozone, nitrate radicals, or singlet oxygen are too slow to be environmentally significant. 1,2-Dichloroethene has significant water solubility and may migrate to, and with, groundwater from the point of its release.

Most studies indicate that both isomers of 1,2-dichloroethene are highly resistant to biodegradation in an aerobic environment but may biodegrade under anaerobic conditions. Anaerobic biodegradation of cis-and trans-1,2-dichloroethene can produce vinyl chloride, which is a hazardous chemical substance. Based on the high measured vapor pressure and large estimated Henry’s law constant, volatilization of 1,2-dichloroethene from water is expected to be an important fate process.

Exposure to 1,2-dichloroethene originates from anthropogenic sources. Since 1,2-dichloroethene is a volatile liquid at room temperature, the most likely route of exposure would be from breathing air containing 1,2-dichloroethene. Occurrences of 1,2-dichloroethene in air can be attributed to releases from factories that manufacture or use 1,2-dichloroethene and/or evaporation from some landfills, solvents, and refrigerants.

Occupational exposure to trans- and cis-1,2-dichloroethene is most likely to occur through inhalation of vapors and aerosols or their deposition onto the skin. The general population is most likely exposed by inhalation of 1,2-dichloroethene vapors arising from contaminated water or intruding into buildings from contaminated soil or groundwater and ingestion of contaminated food and drinking water.

## 1.2 SUMMARY OF HEALTH EFFECTS

For this profile, toxicity studies for 1,2-dichloroethene are categorized by isomer composition: trans-1,2-dichloroethene; cis-1,2-dichloroethene; and mixtures of the cis- and trans- isomers. Only a few studies investigating health effects from exposure to 1,2-dichloroethene in humans were identified, with data limited to studies on trans-1,2-dichloroethene. Information on the health effects in experimental animals is available as follows:

- trans-1,2-dichloroethene: acute- and intermediate-duration oral and inhalation exposures and acute-duration dermal exposure;
- cis-1,2-dichloroethene: acute-duration inhalation exposure and acute- and intermediate-duration oral exposures; and
- mixtures of cis- and trans-1,2-dichloroethene: acute-duration inhalation exposure and acute- and intermediate-duration oral exposures.

No studies on chronic-duration exposure to trans-1,2-dichloroethene, cis-1,2-dichloroethene, or mixtures of cis- and trans- isomers were identified for any exposure route in animals.

For trans-1,2-dichloroethene, the most sensitive effect of acute-duration exposure to trans-1,2-dichloroethene vapor in air is lacrimation (Hurtt et al. 1993), and the most sensitive effect of intermediate-duration oral exposure is on the immune system (decreased humoral immunity) (Shopp et al. 1985), as shown in Figures 1-1 and 1-2, respectively. Dermal exposure studies also indicate that trans-1,2-dichloroethene can damage the skin. ATSDR conducted a systematic review assessing ocular irritation and decreased immune function. Studies on cis-1,2-dichloroethene and mixtures of cis- and trans-1,2-dichlorothene did not identify toxicologically significant effects at sublethal levels.

Figure 1-1 Health Effects Found in Animals Following Inhalation Exposure to trans-1,2-Dichloroethene*

*No intermediate- or chronic-duration MRLs were derived for trans-1,2-dichloroethene

Figure 1-2 Health Effects Found in Animals Following Oral Exposure to trans-1,2-Dichloroethene*

*No acute- or chronic-duration MRLs were derived for trans-1,2-dichloroethene

Information on the most sensitive effects of trans-1,2-dichloroethene is summarized as follows.

Ocular Effects. Exposure to trans-1,2-dichloroethene vapor in air produced statistically significant, dose-related increases in lacrimation frequency in pregnant rats following exposure to 2,000, 6,000, and 12,000 ppm (Hurtt et al. 1993). Brown, periocular staining, due to excessive lacrimation, was observed in the 6,000 ppm (18/24) and 12,000 ppm (22/24) exposure groups compared to one animal affected in the control group. Instillation of 0.01 mL undiluted trans-1,2-dichloroethene to the eyes of rabbits for 20 seconds resulted in transient severe corneal opacity, moderate iritis, and conjunctivitis (DuPont 1988c).

Immunological Effects. Immunological function has been assessed in acute- and intermediate-duration oral exposure studies (Munson et al. 1982; Shopp et al. 1985). Humoral immunity, as measured by the number of spleen immunoglobulin M (IgM) antibody-forming cells (AFCs) directed against sheep red blood cells (sRBCs), was decreased in a statistically significant, dose-related manner in mice following oral exposure to trans-1,2-dichloroethene at doses of 175 and 387 mg/kg/day for 90 days (Shopp et al. 1985). Cellular immune function was not affected. No additional intermediate-duration oral exposure studies evaluating immune studies were identified. No effects on humoral or cellular immunity were observed in acute-duration oral studies in mice at doses up to 220 mg/kg/day for 14 days (Munson et al. 1982; Shopp et al. 1985).

Other effects observed in laboratory animals exposed to trans-1,2-dichloroethene are summarized below, although these effects do not appear to be sensitive targets. Some of these effects may be toxicologically significant; however, results are not consistent across studies.

Body Weight Effects. Body weight depression ≥10% is considered toxicologically significant. Conflicting results have been observed regarding decreased body weight and body weight gain. Maternal body weight gain was reduced 33.8% on gestational day (GD) 16 in pregnant rats exposed via inhalation to 12,000 ppm trans-1,2-dichloroethene on GDs 7–16 (Hurtt et al. 1993), although body weight was similar to controls at the end of pregnancy. In contrast, no effect on body weight was observed in male or female rats following inhalation of 4,000 ppm trans-1,2-dichloroethene for 90 days (DuPont 1998). Final body weight was also decreased in female mice (10.7%) following dietary exposure to 7,925 mg/kg/day for 14 weeks (NTP 2002). Other studies found no effects of oral acute-duration exposures to trans-1,2-dichloroethene in rats or mice at generally lower maximum oral doses tested of 210-220 mg/kg/day (Barnes et al. 1985; Munson et al. 1982) or 387-3,245 mg/kg/day (Barnes et al. 1985; Hayes et al. 1987; NTP 2002), respectively.

Hematological Effects. Results of studies of effects of trans-1,2-dichloroethene on hematological parameters are inconsistent. Statistically significant, dose-related decreases in erythrocyte counts were observed in rats exposed to dietary trans-1,2-dichloroethene for 14 weeks. The no-observed-adverse-effect level (NOAEL) and lowest-observed-adverse-effect level (LOAEL) values were 190 and 380 mg/kg/day, respectively, in males and 780 and 1,580 mg/kg/day, respectively, in females. However, no adverse hematological effects were observed in other oral exposure studies, including an acute-duration exposure of mice to maximum doses of 210 mg/kg/day (Barnes et al. 1985), a 90-day feed studies in rats and mice at doses up to 3,245 and 8,065 mg/kg/day, respectively (NTP 2002), and a 90-day drinking water study at doses up to 2,809 and 3,114 mg/kg/day in male and female rats, respectively (Hayes et al. 1987). In addition, no hematological effects were observed in rats exposed to 4,000 ppm for 90 days by inhalation (DuPont 1998).

Neurological Effects. Little information on neurological effects of trans-1,2-dichloroethene is available. At sublethal levels, narcosis (incidence data not reported) was observed in pregnant female rats while in the whole-body inhalation exposure chamber 6 hours/day on GDs 7-16 at concentrations of 6,000 and 12,000 ppm, but not at 2,000 ppm (Hurtt et al. 1993). Following removal from the exposure chamber, lethargy was observed in rats exposed to 12,000 ppm, but not at lower exposure concentrations (Hurtt et al. 1993). In single-dose oral lethality studies in rats, clinical signs of neurotoxicity (central nervous system depression, decreased activity, ataxia, loss of righting reflex, and depressed respiration) have been observed (Barnes et al. 1985; Hayes et al. 1987); however, due to the lack of incidence data, reliable NOAEL and LOAEL values could not be identified. No neurotoxicity (assessed by functional observational batteries, cage-side evaluations for clinical signs, and histopathology of neurological tissues) was observed in male and female rats at maximum doses of 3,210 and 3,245 mg/kg/day, respectively, or in male and female mice at maximum doses of 8,065 and 7,925 mg/kg/day, respectively, in a 14-week microencapsulation feed study (NTP 2002).

Developmental Effects. An epidemiological study did not find associations between maternal exposure to trans-1,2-dichloroethene during pregnancy and birth defects (neural tube defect or oral cleft defects (Ruckart et al. 2013). A gestational exposure study in rats observed statistically significantly increased resorptions following inhalation exposure to 6,000 ppm trans-1,2-dichloroethene and decreased fetal weight in females at 12,000 ppm (Hurtt et al. 1993). No additional developmental studies were identified for trans-1,2-dichloroethene.

Carcinogenic Effects. 1,2-Dichloroethene is not listed by Department of Health and Human Services (HHS) National Toxicology Program (NTP) in the 15^th^ Report on Carcinogens (NTP 2021). The U.S. Environmental Protection Agency (EPA) has not classified the carcinogenicity of 1,2-dichloroethene due to inadequate information (IRIS 2010a, 2010b). The International Agency for Research on Cancer (IARC) has not evaluated the carcinogenicity of 1,2-dichloroethene (IARC 2024).

## 1.3 MINIMAL RISK LEVELS (MRLs)

Development of MRLs was considered for the individual cis- and trans- isomers, but not for mixtures of the isomers. The database for trans-1,2-dichloroethene was considered adequate to derive an acute-duration inhalation MRL and an intermediate-duration oral MRL. The MRL values for trans-1,2-dichloroethene are summarized in Table 1-1. As presented in Figures 1-3 and 1-4, available data for trans-1,2-dichloroethene show that lacrimation and effects on the immune system function are the most sensitive effects for exposure to 1,2-dichloroethene vapor in air and oral exposure, respectively. Intermediate- and chronic-duration inhalation MRLs and acute- and chronic-duration oral MRLs for trans-1,2-dichloroethene were not derived due to inadequate data. For cis-1,2-dichloroethene, no inhalation or oral MRLs for any exposure duration were derived due to inadequate data (Table 1-2).

Figure 1-3 Summary of Sensitive Targets of trans-1,2-Dichloroethene -Inhalation

Available data indicate that the eye is the most sensitive target of trans-1,2-dichloroethene inhalation exposure.

Numbers in circles are the lowest LOAELs for all health effects in animals; exposure data for humans are uncertain.

Figure 1-4 Summary of Sensitive Targets of trans-1,2-Dichloroethene – Oral

Available data indicate that the immune system is the most sensitive target of trans-1,2-dichloroethene oral exposure.

Numbers in circles are the lowest LOAELs for all health effects in animals; exposure data for humans are uncertain.

Table 1-1 Minimal Risk Levels (MRLs) for trans-1,2-Dichloroethene^a^

Exposure route | Exposure duration | MRL | Critical effect | POD type | POD value | Uncertainty/modifying factor | Reference
Inhalation | Acute | 3 ppm (12 mg/m^3^) | Lacrimation | BMCL_10_ | 256.47 ppm | UF: 100 | Hurtt et al. 1993
Inhalation | Intermediate | None | – | – | – | – | –
Inhalation | Chronic | None | – | – | – | – | –
Oral | Acute | None | – | – | – | – | –
Oral | Intermediate | 0.2 mg/kg/day | Decreased humoral immunity | BMDL_1SD_ | 16.75 mg/kg/day | UF: 100 | Shopp et al. 1985
Oral | Chronic | None | – | – | – | – | –

a See Appendix A for additional information.

BMCL_10_ = 95% lower confidence limit on the benchmark concentration (subscripts denote benchmark response: i.e., 10 = dose associated with 10% extra risk); BMDL = 95% lower confidence limit on the benchmark dose; HEC = human equivalent concentration; LOAEL = lowest-observed-adverse-effect level; POD = point of departure; SD = standard deviation; UF = uncertainty factor

Table 1-2 Minimal Risk Levels (MRLs) for cis-1,2-Dichloroethene^a^

No MRLs were derived for any exposure route or duration for cis-1,2-dichloroethene.

a See Appendix A for additional information.