# APPENDIX B LITERATURE SEARCH FRAMEWORK FOR 1,2-DICHLOROETHENE

The objective of the toxicological profile is to evaluate the potential for human exposure and the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to 1,2-dichloroethene.

## B.1 LITERATURE SEARCH AND SCREEN

A literature search and screen were conducted to identify studies examining health effects, toxicokinetics, mechanisms of action, susceptible populations, biomarkers, chemical interactions, physical and chemical properties, production, use, environmental fate, environmental releases, and environmental and biological monitoring data for 1,2-dichloroethene. ATSDR primarily focused on peer-reviewed articles without language restrictions. Foreign language studies are reviewed based on available English-language abstracts and/or tables (or summaries in regulatory assessments, such as International Agency for Research on Cancer [IARC] documents). If the study appears critical for hazard identification or MRL derivation, translation into English is requested. Non-peer-reviewed studies that were considered relevant to the assessment of the health effects of 1,2-dichloroethene have undergone peer review by at least three ATSDR-selected experts who have been screened for conflict of interest. The inclusion criteria used to identify relevant studies examining the health effects of 1,2-dichloroethene are presented in Table B-1.

Table B-1 Inclusion Criteria for the Literature Search and Screen

Health Effects
Species
Human
Laboratory mammals
Route of exposure
Inhalation
Oral
Dermal (or ocular)
Parenteral (these studies will be considered supporting data)
Health outcome
Death
Systemic effects
Body weight effects
Respiratory effects
Cardiovascular effects
Gastrointestinal effects
Hematological effects
Musculoskeletal effects
Hepatic effects
Renal effects
Dermal effects
Ocular effects
Endocrine effects
Immunological effects
Neurological effects
Reproductive effects
Developmental effects
Other noncancer effects
Cancer
Toxicokinetics
Absorption
Distribution
Metabolism
Excretion
PBPK models
Biomarkers
Biomarkers of exposure
Biomarkers of effect
Interactions with other chemicals
Potential for human exposure
Releases to the environment
Air
Water
Soil
Environmental fate
Transport and partitioning
Transformation and degradation
Environmental monitoring
Air
Water
Sediment and soil
Other media
Biomonitoring
General populations
Occupation populations

### B.1.1 Literature Search

The literature search was conducted to update the Toxicological Profile for 1,2-Dichloroethene released in 1996. All literature cited in the previous (1996) toxicological profile were considered for inclusion in the updated profile. The initial literature search, which was performed in May 2017 and October 2021, was restricted to studies added to databases since January 1994. An updated literature search was performed after the Toxicological Profile for 1,2-Dichloroethene Draft for Public Comment was released in August 2023 to identify any additional studies added to databases between September 2021 and December 2023.

The following main databases were searched in May 2017, October 2021, and/or December 2023:

- PubMed
- National Technical Reports Library (NTRL)
- Scientific and Technical Information Network’s TOXCENTER
- National Library of Medicine’s TOXLINE (May 2017 only)

The search strategy used the chemical names, Chemical Abstracts Service (CAS) numbers, synonyms, Medical Subject Headings (MeSH) headings, and keywords for 1,2-dichloroethene. The query strings used for the literature search are presented in Table B-2.

The search was augmented by searching the Toxic Substances Control Act Test Submissions (TSCATS), NTP website, and National Institute of Health Research Portfolio Online Reporting Tools Expenditures and Results (NIH RePORTER) databases using the queries presented in Table B-3. Additional databases were searched in the creation of various tables and figures, such as the TRI Explorer, the Substance Priority List (SPL) resource page, and other items as needed. Regulations applicable to 1,2-dichloroethene were identified by searching international and U.S. agency websites and documents.

Review articles were identified and used for the purpose of providing background information and identifying additional references. ATSDR also identified reports from the grey literature, which included unpublished research reports, technical reports from government agencies, conference proceedings and abstracts, and theses and dissertations.

Table B-2 Database Query Strings

Database search date | Query string
PubMed
12/2023 | ((540–59-0[rn] OR 156–59-2[rn] OR 156–60-5[rn] OR 25323–30-2[rn] OR "1,2-dichloroethylene"[nm]) AND 2021/09/01:3000[mhda]) OR (("1,2-DCE"[tw] OR "1,2-Dichlor-aethen"[tw] OR "1,2-Dichloroethene"[tw] OR "1,2-Dichloroethylene"[tw] OR "Acetylene dichloride"[tw] OR "Dichloro-1,2-ethylene"[tw] OR "Dioform"[tw] OR "sym-Dichloroethylene"[tw] OR "(Z)-1,2-Dichloroethene"[tw] OR "(Z)-1,2-Dichloroethylene"[tw] OR "Acetalyne dichloride"[tw] OR "cis-Acetylene dichloride "[tw] OR "cis-1,2-Dichloroethene"[tw] OR "cis-1,2-Dichloroethylene"[tw] OR "cis-Dichloroethylene"[tw] OR "HCC 1130c"[tw] OR "R 1130c"[tw] OR "(1Z)-1,2-dichloro-Ethene "[tw] OR "1,2-Dichloroethylene"[tw] OR "(E)-1,2-Dichloroethene"[tw] OR "(E)-1,2-Dichloroethylene"[tw] OR "HCC 1130t"[tw] OR "R 1130t"[tw] OR "trans-1,2-Dichloroethene"[tw] OR "trans-1,2-Dichloroethylene"[tw] OR "trans-Acetylene dichloride"[tw] OR "trans-Dichloroethylene"[tw] OR "(1E)-1,2-dichloro-Ethene"[tw] OR "1,2-Dichloroethylene"[tw] OR "1,2-trans-Dichloroethylene"[tw] OR "Dichloroethene"[tw] OR "Dichloroethenes"[tw] OR "Dichloroethylene"[tw] OR "Dichloroethylenes"[tw]) AND (2021/09/01:3000[edat] OR 2021/09/01:3000[crdat]))
10/2021 | ((540–59-0[rn] OR 156–59-2[rn] OR 156–60-5[rn] OR "1,2-DCE"[tw] OR "1,2-Dichlor-aethen"[tw] OR "1,2-Dichloroethene"[tw] OR "1,2-Dichloroethylene"[tw] OR "Acetylene dichloride"[tw] OR "Dichloro-1,2-ethylene"[tw] OR "Dioform"[tw] OR "sym-Dichloroethylene"[tw] OR "(Z)-1,2-Dichloroethene"[tw] OR "(Z)-1,2-Dichloroethylene"[tw] OR "Acetalyne dichloride"[tw] OR "cis-Acetylene dichloride "[tw] OR "cis-1,2-Dichloroethene"[tw] OR "cis-1,2-Dichloroethylene"[tw] OR "cis-Dichloroethylene"[tw] OR "HCC 1130c"[tw] OR "R 1130c"[tw] OR "(1Z)-1,2-dichloro-Ethene "[tw] OR "1,2-Dichloroethylene"[tw] OR "(E)-1,2-Dichloroethene"[tw] OR "(E)-1,2-Dichloroethylene"[tw] OR "HCC 1130t"[tw] OR "R 1130t"[tw] OR "trans-1,2-Dichloroethene"[tw] OR "trans-1,2-Dichloroethylene"[tw] OR "trans-Acetylene dichloride"[tw] OR "trans-Dichloroethylene"[tw] OR "(1E)-1,2-dichloro-Ethene"[tw] OR "1,2-Dichloroethylene"[tw] OR "1,2-trans-Dichloroethylene"[tw]) AND (1994/01/01 : 3000[dp] OR 1994/01/01 : 3000[mhda] OR 1994/01/01 : 3000[edat])) OR ((("Dichloroethenes"[tw] OR "Dichloroethene"[tw] OR "Dichloroethylene"[tw] OR "1,2-Dichloroethylene"[tw]) AND (1994/01/01 : 3000[dp] OR 1994/01/01 : 3000[mhda] OR 1994/01/01 : 3000[edat])) NOT medline[sb])
Toxline
05/2017 | ( "1 2-dce" OR "1 2-dichlor-aethen" OR "1 2-dichloroethene" OR "1 2-dichloroethylene" OR "acetylene dichloride" OR "dichloro-1 2-ethylene" OR "dioform" OR "sym-dichloroethylene" OR " ( z ) -1 2-dichloroethene" OR " ( z ) -1 2-dichloroethylene" OR "acetalyne dichloride" OR "cis-acetylene dichloride " OR "cis-1 2-dichloroethene" OR "cis-1 2-dichloroethylene" OR "cis-dichloroethylene" OR "hcc 1130c" OR "r 1130c" OR " ( 1z ) -1 2-dichloro-ethene " OR "1 2-dichloroethylene" OR " ( e ) -1 2-dichloroethene" OR " ( e ) -1 2-dichloroethylene" OR "hcc 1130t" OR "r 1130t" OR "trans-1 2-dichloroethene" OR "trans-1 2-dichloroethylene" OR "trans-acetylene dichloride" OR "trans-dichloroethylene" OR " ( 1e ) - 1 2-dichloro-ethene" OR "1 2-dichloroethylene" OR "1 2-trans-dichloroethylene" OR "dichloroethenes" OR "dichloroethene" OR "dichloroethylene" OR "1 2-dichloroethylene" OR 540–59-0 [rn] OR 156–59-2 [rn] OR 156–60-5 [rn] OR 25323–30-2 [rn] ) AND 1999:2017 [yr] AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) AND NOT PubMed [org] AND NOT pubdart [org]
| ( "1 2-dce" OR "1 2-dichlor-aethen" OR "1 2-dichloroethene" OR "1 2-dichloroethylene" OR "acetylene dichloride" OR "dichloro-1 2-ethylene" OR "dioform" OR "sym-dichloroethylene" OR " ( z ) -1 2-dichloroethene" OR " ( z ) -1 2-dichloroethylene" OR "acetalyne dichloride" OR "cis-acetylene dichloride " OR "cis-1 2-dichloroethene" OR "cis-1 2-dichloroethylene" OR "cis-dichloroethylene" OR "hcc 1130c" OR "r 1130c" OR " ( 1z ) -1 2-dichloro-ethene " OR "1 2-dichloroethylene" OR " ( e ) -1 2-dichloroethene" OR " ( e ) -1 2-dichloroethylene" OR "hcc 1130t" OR "r 1130t" OR "trans-1 2-dichloroethene" OR "trans-1 2-dichloroethylene" OR "trans-acetylene dichloride" OR "trans-dichloroethylene" OR " ( 1e ) 1 2-dichloro-ethene" OR "1 2-dichloroethylene" OR "1 2-trans-dichloroethylene" OR "dichloroethenes" OR "dichloroethene" OR "dichloroethylene" OR "1 2-dichloroethylene" OR 540–59-0 [rn] OR 156–59-2 [rn] OR 156–60-5 [rn] OR 25323–30-2 [rn] ) AND 1994:1998 [yr] AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) AND NOT PubMed [org] AND NOT pubdart [org]
NTRL
12/2023 | Date Published 2020 to 2023; "1,2-DCE" OR "1,2-Dichlor-aethen" OR "1,2-Dichloroethene" OR "1,2-Dichloroethylene" OR "Acetylene dichloride" OR "Dichloro-1,2-ethylene" OR "Dioform" OR "sym-Dichloroethylene" OR "(Z)-1,2-Dichloroethene" OR "(Z)-1,2-Dichloroethylene" OR "Acetalyne dichloride" OR "cis-Acetylene dichloride " OR "cis-1,2-Dichloroethene" OR "cis-1,2-Dichloroethylene" OR "cis-Dichloroethylene" OR "HCC 1130c" OR "R 1130c" OR "(1Z)-1,2-dichloro-Ethene " OR "1,2-Dichloroethylene" OR "(E)-1,2-Dichloroethene" OR "(E)-1,2-Dichloroethylene" OR "HCC 1130t" OR "R 1130t" OR "trans-1,2-Dichloroethene" OR "trans-1,2-Dichloroethylene" OR "trans-Acetylene dichloride" OR "trans-Dichloroethylene" OR "(1E)-1,2-dichloro-Ethene" OR "1,2-Dichloroethylene" OR "1,2-trans-Dichloroethylene" OR "Dichloroethene" OR "Dichloroethenes" OR "Dichloroethylene" OR "Dichloroethylenes"
10/2021 | "1,2-DCE" OR "1,2-Dichlor-aethen" OR "1,2-Dichloroethene" OR "1,2-Dichloroethylene" OR "Acetylene dichloride" OR "Dichloro-1,2-ethylene" OR "Dioform" OR "sym-Dichloroethylene" OR "(Z)-1,2-Dichloroethene" OR "(Z)-1,2-Dichloroethylene" OR "Acetalyne dichloride" OR "cis-Acetylene dichloride" OR "cis-1,2-Dichloroethene" OR "cis-1,2-Dichloroethylene" OR "cis-Dichloroethylene" OR "HCC 1130c" OR "R 1130c" OR "(1Z)-1,2-dichloro-Ethene " OR "1,2-Dichloroethylene" OR "(E)-1,2-Dichloroethene" OR "(E)-1,2-Dichloroethylene" OR "HCC 1130t" OR "R 1130t" OR "trans-1,2-Dichloroethene" OR "trans-1,2-Dichloroethylene" OR "trans-Acetylene dichloride" OR "trans-Dichloroethylene" OR "(1E)-1,2-dichloro-Ethene" OR "1,2-Dichloroethylene" OR "1,2-trans-Dichloroethylene" OR "Dichloroethenes" OR "Dichloroethene" OR "Dichloroethylene"
Toxcenter
12/2023 | FILE 'TOXCENTER' ENTERED AT 15:00:27 ON 14 DEC 2023; L1 6007 SEA 540-59-0 OR 156-59-2 OR 156-60-5 OR 25323-30-2 L2 5247 SEA L1 NOT PATENT/DT; L3 230 SEA L2 AND ED>=20210901; L40 226 DUP REM L3 (4 DUPLICATES REMOVED) D SCAN L40
10/2021 | FILE 'TOXCENTER' ENTERED AT 14:43:29 ON 05 OCT 2021 CHARGED TO COST=EH038.10.01.04; L1 5720 SEA FILE=TOXCENTER 540-59-0 OR 156-59-2 OR 156-60-5 OR 25323-30-2; L2 5589 SEA FILE=TOXCENTER L1 NOT TSCATS/FS L3 4869 SEA FILE=TOXCENTER L2 NOT PATENT/DT; L4 340 SEA FILE=TOXCENTER L3 AND ED>20170501; ACT TOXQUERY/Q; ---------; L5 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?); L6 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST,CT, IT); L7 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50); L8 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT; L9 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?); L10 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?) L11 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS OR DIETARY OR DRINKING(W)WATER?); L12 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE)); L13 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?); L14 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM? OR OVUM?); L15 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?); L16 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?); L17 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? OR SPERMATOB? OR SPERMATOC? OR SPERMATOG?); L18 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?); L19 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?); L20 QUE (ENDOCRIN? AND DISRUPT?); L21 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?); L22 QUE (WEAN? OR OFFSPRING OR AGE(W)FACTOR?); L23 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?); L24 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER? OR NEOPLAS?); L25 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?); L26 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?); L27 QUE (NEPHROTOX? OR HEPATOTOX?); L28 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?); L29 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?); L30 QUE L5 OR L6 OR L7 OR L8 OR L9 OR L10 OR L11 OR L12 OR L13 OR L14 OR L15 OR L16 OR L17 OR L18 OR L19 OR L20 OR L21 OR L22 OR L23 OR L24 OR L25 OR L26 OR L27 OR L28 OR L29; L31 QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR MURIDAE OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR SWINE OR PORCINE OR MONKEY? OR MACAQUE?); L32 QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR LAGOMORPHA; OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE); L33 QUE L30 OR L31 OR L32; L34 QUE (NONHUMAN MAMMALS)/ORGN; L35 QUE L33 OR L34; L36 QUE (HUMAN OR HUMANS OR HOMINIDAE OR MAMMALS OR MAMMAL? OR PRIMATES OR PRIMATE?); L37 QUE L35 OR L36; ---------; L38 133 SEA FILE=TOXCENTER L4 AND L37; L39 4 SEA FILE=TOXCENTER L38 AND MEDLINE/FS; L40 7 SEA FILE=TOXCENTER L38 AND BIOSIS/FS; L41 122 SEA FILE=TOXCENTER L38 AND CAPLUS/FS; L42 0 SEA FILE=TOXCENTER L38 NOT (MEDLINE/FS OR BIOSIS/FS OR CAPLUS/FS); L43 131 DUP REM L39 L40 L41 (2 DUPLICATES REMOVED) D SCAN L43; L44 935 SEA FILE=TOXCENTER 25323-30-2; L45 924 SEA FILE=TOXCENTER L44 NOT TSCATS/FS; L46 688 SEA FILE=TOXCENTER L45 NOT PATENT/DT; L47 40 SEA FILE=TOXCENTER L46 AND ED>20170501; L48 13 SEA FILE=TOXCENTER L47 AND L37; L*** DEL 4 S L38 AND MEDLINE/FS; L*** DEL 4 S L38 AND MEDLINE/FS; L49 4 SEA FILE=TOXCENTER L43; L*** DEL 7 S L38 AND BIOSIS/FS; L*** DEL 7 S L38 AND BIOSIS/FS; L50 7 SEA FILE=TOXCENTER L43; L*** DEL 122 S L38 AND CAPLUS/FS; L*** DEL 122 S L38 AND CAPLUS/FS; L51 120 SEA FILE=TOXCENTER L43; L52 0 SEA FILE=TOXCENTER L48 NOT (L49 OR L50 OR L51)
05/2017 | (FILE 'HOME' ENTERED AT 09:05:27 ON 05 APR 2017); FILE 'TOXCENTER' ENTERED AT 09:05:48 ON 05 APR 2017 CHARGED TO COST=EH011.13.01.01; L1 4437 SEA 540-59-0 OR 156-59-2 OR 156-60-5; L2 859 SEA 25323-30-2; L3 5208 SEA L1 OR L2; L4 5077 SEA L3 NOT TSCATS/FS; L5 4442 SEA L4 NOT PATENT/DT; L6 2662 SEA L5 AND PY>=1999; ACTIVATE TOXQUERY/Q; ---------; L7 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?); L8 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST,CT, IT); L9 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50); L10 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT; L11 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?); L12 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?); L13 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS OR DIETARY OR DRINKING(W)WATER?); L14 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE)); L15 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?); L16 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM? OR OVUM?); L17 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?); L18 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?); L19 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? OR SPERMATOB? OR SPERMATOC? OR SPERMATOG?); L20 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR SPERMATOZ? OR; SPERMATU? OR SPERMI? OR SPERMO?); L21 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?); L22 QUE (ENDOCRIN? AND DISRUPT?); L23 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?); L24 QUE (WEAN? OR OFFSPRING OR AGE(W)FACTOR?); L25 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?); L26 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER? OR NEOPLAS?); L27 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?); L28 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?); L29 QUE (NEPHROTOX? OR HEPATOTOX?); L30 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?); L31 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?); L32 QUE L7 OR L8 OR L9 OR L10 OR L11 OR L12 OR L13 OR L14 OR L15 OR L16 OR L17 OR L18 OR L19 OR L20 OR L21 OR L22 OR L23 OR L24 OR L25 OR L26 OR L27 OR L28 OR L29 OR L30 OR L31; L33 QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR MURIDAE OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR SWINE OR PORCINE OR MONKEY? OR MACAQUE?); L34 QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR LAGOMORPHA OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE); L35 QUE L32 OR L33 OR L34; L36 QUE (NONHUMAN MAMMALS)/ORGN; L37 QUE L35 OR L36; L38 QUE (HUMAN OR HUMANS OR HOMINIDAE OR MAMMALS OR MAMMAL? OR PRIMATES OR PRIMATE?); L39 QUE L37 OR L38; ---------; L40 647 SEA L6 AND L39; L41 36 SEA L40 AND MEDLINE/FS; L42 31 SEA L40 AND BIOSIS/FS; L43 574 SEA L40 AND CAPLUS/FS; L44 6 SEA L40 NOT (MEDLINE/FS OR BIOSIS/FS OR CAPLUS/FS); L45 621 DUP REM L41 L42 L44 L43 (26 DUPLICATES REMOVED); L*** DEL 36 S L40 AND MEDLINE/FS; L*** DEL 36 S L40 AND MEDLINE/FS; L46 36 SEA L45; L*** DEL 31 S L40 AND BIOSIS/FS; L*** DEL 31 S L40 AND BIOSIS/FS; L47 30 SEA L45; L*** DEL 574 S L40 AND CAPLUS/FS; L*** DEL 574 S L40 AND CAPLUS/FS L48 549 SEA L45; L*** DEL 6 S L40 NOT (MEDLINE/FS OR BIOSIS/FS OR CAPLUS/FS); L*** DEL 6 S L40 NOT (MEDLINE/FS OR BIOSIS/FS OR CAPLUS/FS); L49 6 SEA L45; L50 585 SEA (L46 OR L47 OR L48 OR L49) NOT MEDLINE/FS; L51 510 SEA L50 NOT 25323-30-2; D SCAN L51; L52 75 SEA L50 NOT L51; D SCAN L52; (FILE 'HOME' ENTERED AT 11:02:51 ON 31 MAY 2017); FILE 'TOXCENTER' ENTERED AT 11:03:35 ON 31 MAY 2017; CHARGED TO COST=EH011.13.01.01; L1 5239 SEA 540-59-0 OR 156-59-2 OR 156-60-5 OR 25323-30-2; L2 5108 SEA L1 NOT TSCATS/FS; L3 4469 SEA L2 NOT PATENT/DT; L4 765 SEA L3 AND PY>=1994 AND PY<=1998; ACTIVATE TOXQUERY/Q; ---------; L5 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?); L6 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST,CT, IT); L7 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50); L8 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT; L9 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?); L10 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?); L11 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS OR DIETARY OR DRINKING(W)WATER?); L12 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE)); L13 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?); L14 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM? OR OVUM?); L15 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?); L16 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?); L17 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? OR SPERMATOB? OR SPERMATOC? OR SPERMATOG?); L18 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR; SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?); L19 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?); L20 QUE (ENDOCRIN? AND DISRUPT?); L21 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?); L22 QUE (WEAN? OR OFFSPRING OR AGE(W)FACTOR?); L23 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?); L24 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER? OR NEOPLAS?); L25 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?); L26 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?); L27 QUE (NEPHROTOX? OR HEPATOTOX?); L28 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?); L29 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?); L30 QUE L5 OR L6 OR L7 OR L8 OR L9 OR L10 OR L11 OR L12 OR L13 OR L14 OR L15 OR L16 OR L17 OR L18 OR L19 OR L20 OR L21 OR L22 OR L23 OR L24 OR L25 OR L26 OR L27 OR L28 OR L29; L31 QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR MURIDAE OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR SWINE OR PORCINE OR MONKEY? OR MACAQUE?); L32 QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR LAGOMORPHA; OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE); L33 QUE L30 OR L31 OR L32; L34 QUE (NONHUMAN MAMMALS)/ORGN; L35 QUE L33 OR L34; L36 QUE (HUMAN OR HUMANS OR HOMINIDAE OR MAMMALS OR MAMMAL? OR PRIMATES OR PRIMATE?); L37 QUE L35 OR L36; ---------; L38 190 SEA L4 AND L37; L39 8 SEA L38 AND MEDLINE/FS; L40 15 SEA L38 AND BIOSIS/FS; L41 159 SEA L38 AND CAPLUS/FS; L42 8 SEA L38 NOT (MEDLINE/FS OR BIOSIS/FS OR CAPLUS/FS); L43 170 DUP REM L39 L40 L42 L41 (20 DUPLICATES REMOVED); L*** DEL 8 S L38 AND MEDLINE/FS; L*** DEL 8 S L38 AND MEDLINE/FS; L44 8 SEA L43; L*** DEL 15 S L38 AND BIOSIS/FS; L*** DEL 15 S L38 AND BIOSIS/FS L45 12 SEA L43; L*** DEL 159 S L38 AND CAPLUS/FS; L*** DEL 159 S L38 AND CAPLUS/FS; L46 143 SEA L43; L*** DEL 8 S L38 NOT (MEDLINE/FS OR BIOSIS/FS OR CAPLUS/FS); L*** DEL 8 S L38 NOT (MEDLINE/FS OR BIOSIS/FS OR CAPLUS/FS); L47 7 SEA L43; L48 162 SEA (L44 OR L45 OR L46 OR L47) NOT MEDLINE/FS; D SCAN L48

Table B-3 Strategies to Augment the Literature Search

Source | Query and number screened when available
TSCATS via ChemView
12/2023; 10/2021 | Compounds searched: 540-59-0; 156-59-2; 156-60-5; 25323-30-2
NTP
12/2023 | Date limited 2020-present; "540-59-0" "156-60-5" "Dichloroethene" "Dichloroethylene"; "156-59-2" "25323-30-2" "1,2-Dichloroethene" "1,2-Dichloroethylene"; "Acetylene dichloride"; "Dichloroethylenes" "Dichloroethenes"
10/2021 | "540-59-0" "156-59-2" "156-60-5" "25323-30-2"; "Dichloroethene" "Dichloroethylene" "Acetylene dichloride" "Dichloroethylenes"
Regulations.gov
12/2023 | Restricted to docket or EPA notices: "156-60-5"; "540-59-0"; "156-59-2"; "25323-30-2"; dichloroethylene dichloroethene
NIH RePORTER
9/2024 | Search Criteria: Fiscal Year: Active Projects Text Search: "1,2-DCE" OR "1,2-Dichlor-aethen" OR "1,2-Dichloroethene" OR "1,2-Dichloroethylene" OR "Acetylene dichloride" OR "Dichloro-1,2-ethylene" OR "Dioform" OR "sym-Dichloroethylene" OR "(Z)-1,2-Dichloroethene" OR "(Z)-1,2-Dichloroethylene" OR "Acetalyne dichloride" OR "cis-Acetylene dichloride " OR "cis-1,2-Dichloroethene" OR "cis-1,2-Dichloroethylene" OR "cis-Dichloroethylene" OR "HCC 1130c" OR "R 1130c" OR "(1Z)-1,2-dichloro-Ethene " OR "1,2-Dichloroethylene" OR "(E)-1,2-Dichloroethene" OR "(E)-1,2-Dichloroethylene" OR "HCC 1130t" OR "R 1130t" OR "trans-1,2-Dichloroethene" OR "trans-1,2-Dichloroethylene" OR "trans-Acetylene dichloride" OR "trans-Dichloroethylene" OR "(1E)-1,2-dichloro-Ethene" OR "1,2-Dichloroethylene" OR "1,2-trans-Dichloroethylene" OR "Dichloroethene" OR "Dichloroethenes" OR "Dichloroethylene" OR "Dichloroethylenes" (advanced) Limit to: Project Title, Project Terms, Project Abstracts
05/2022 | " Text Search: "1,2-DCE" OR "1,2-Dichlor-aethen" OR "1,2-Dichloroethene" OR "1,2-Dichloroethylene" OR "Acetylene dichloride" OR "Dichloro-1,2-ethylene" OR "Dioform" OR "sym-Dichloroethylene" OR "(Z)-1,2-Dichloroethene" OR "(Z)-1,2-Dichloroethylene" OR "Acetalyne dichloride" OR "cis-Acetylene dichloride " OR "cis-1,2-Dichloroethene" OR "cis-1,2-Dichloroethylene" OR "cis-Dichloroethylene" OR "HCC 1130c" OR "R 1130c" OR "(1Z)-1,2-dichloro-Ethene " OR "1,2-Dichloroethylene" OR "(E)-1,2-Dichloroethene" OR "(E)-1,2-Dichloroethylene" OR "HCC 1130t" OR "R 1130t" OR "trans-1,2-Dichloroethene" OR "trans-1,2-Dichloroethylene" OR "trans-Acetylene dichloride" OR "trans-Dichloroethylene" OR "(1E)-1,2-dichloro-Ethene" OR "1,2-Dichloroethylene" OR "1,2-trans-Dichloroethylene" (advanced); " Limit to: Project Title, Project Terms, Project Abstracts
Other | Includes additional reference identified throughout the assessment process, which may include studies found by tree searching; recommended by intraagency, interagency, peer, or public reviewers; or published more recently than the date of literature search(es). Additional references include those for specific regulations or guidelines and publications found by targeted searches for specific information (e.g., searches for reviews of general [not chemical-specific] mechanisms of toxicity).

The 2021 pre-public comment search results were:

- Number of records identified from PubMed, Toxline, NTRL, and TOXCENTER (after duplicate removal): 1,873
- Number of records identified from other strategies: 99
- Total number of records to undergo literature screening: 1,972

The 2023 post-public comment search results were:

- Number of records identified from PubMed, NTRL, and TOXCENTER (after duplicate removal): 381
- Number of records identified from other strategies: 54
- Total number of records to undergo literature screening: 435

### B.1.2 Literature Screening

A two-step process was used to screen the literature search to identify relevant studies on 1,2-dichloroethene during the pre- and post-public comment drafts:

- Title and abstract screen
- Full text screen

One reviewer conducted screening of the titles, abstracts, and full text articles.

Pre-Public Comment Title and Abstract Screen. Within the reference library, titles and abstracts were screened manually for relevance. Studies that were considered relevant (see Table B-1 for inclusion criteria) were moved to the second step of the literature screening process. Studies were excluded when the title and abstract clearly indicated that the study was not relevant to the toxicological profile.

- Number of titles and abstracts screened: 1,972
- Number of studies considered relevant and moved to the next step: 200

Pre-Public Comment Full Text Screen. The second step in the literature screening process was a full text review of individual studies considered relevant in the title and abstract screen step. Each study was reviewed to determine whether it was relevant for inclusion in the toxicological profile.

- Number of studies undergoing full text review: 200
- Number of studies cited in the previous toxicological profile: 171
- Total number of studies cited in the profile: 266

A summary of the results of the pre-public literature search and screening is presented in Figure B-1.

Figure B-1 October 2021 Pre-Public Comment Literature Search Results and Screen for 1,2-Dichloroethene*

*The chemistry studies category includes studies pertaining to the potential for human exposure (Table B-1). The toxicology studies category includes human and animal studies of health effects as well as studies of toxicokinetics, biomarkers, and interactions with other chemicals (Table B-1). The regulatory studies category includes those studies cited in Chapter 7.

Post-Public Comment Title and Abstract Screen. Within the reference library, titles and abstracts were screened manually for relevance. Studies that were considered relevant (see Table B-1 for inclusion criteria) were moved to the second step of the literature screening process. Studies were excluded when the title and abstract clearly indicated that the study was not relevant to the toxicological profile.

- Number of titles and abstracts screened: 435
- Number of studies considered relevant and moved to the next step: 69

Post-Public Comment Full Text Screen. The second step in the literature screening process was a full text review of individual studies considered relevant in the title and abstract screen step. Each study was reviewed to determine whether it was relevant for inclusion in the toxicological profile.

- Number of studies undergoing full text review: 69
- Number of studies cited in the pre-public draft of the toxicological profile: 266
- Total number of studies cited in the profile: 282

A summary of the results of the post-public comment literature search and screening is presented in Figure B-2.

Figure B-2 December 2023 Post-Public Comment Literature Search Results and Screen for 1,2-Dichloroethene*

*The chemistry studies category includes studies pertaining to the potential for human exposure (Table B-1). The toxicology studies category includes human and animal studies of health effects as well as studies of toxicokinetics, biomarkers, and interactions with other chemicals (Table B-1). The regulatory studies category includes those studies cited in Chapter 7.