# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. LOAELs for serious health effects (such as irreparable damage to the liver or kidneys, or serious birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Office of Innovation and Analytics, Toxicology Section, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Office of Innovation and Analytics, Toxicology Section, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S106–5, Atlanta, Georgia 30329–4027.

## trans-1,2-Dichloroethene Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | trans-1,2-Dichloroethene
CAS Numbers: | 156-60-5
Date: | April 2025
Profile Status: | Final
Route: | Inhalation
Duration: | Acute
MRL: | 3 ppm
Critical Effect: | Lacrimation
Reference: | Hurtt et al. 1993
Point of Departure: | BMCL_10_ of 256.47 ppm
Uncertainty Factor: | 100
LSE Graph Key: | 1
Species: | Rat

MRL Summary: An acute-duration inhalation MRL of 3 ppm was derived for trans-1,2-dichloroethene based on lacrimation in pregnant rats exposed to trans-1,2-dichloroethene vapor in air on GDs 7–16. The MRL is based on a BMCL_10_ of 256.47 ppm (unadjusted for exposure duration because exposure was concentration-dependent, not duration-dependent) and a total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

Selection of the Critical Effect: Few animal studies have investigated effects of acute-duration inhalation exposure to trans-1,2-dichloroethene (Freundt et al. 1977; Gradiski et al. 1978; Hurtt et al. 1993). Gradiski et al. (1978) is an acute lethality study designed to estimate the LC_50_ value for a single 6-hour inhalation exposure to trans-1,2-dichloroethene. No information other than the estimated LC_50_ value (21,723 ppm) was reported. Therefore, this study does not provide suitable data for derivation of the acute-duration inhalation MRL. The Freundt et al. (1977) study examined effects of a single 8-hour exposure to 0, 200, 1,000, or 3,000 ppm in female Wistar rats (n=6). Separate groups of female rats were exposed to 0 or 200 ppm (8 hours/day, 5 days/week) for 1, 2, or 8 weeks. Histological changes to the respiratory tract (capillary hyperemia and alveolar distention) and decreased leukocyte count (24%) were observed at 200 ppm following the single 8-hour exposure. Leukocyte counts were also decreased by 24% at 1,000 ppm (data not reported for 3,000 ppm); therefore, effects did not exhibit dose-dependence. Following exposure to 200 ppm for 1–2 weeks, histological changes were observed to the respiratory tract (capillary hyperemia and alveolar distention), liver (slight fatty accumulation of liver lobules), and immune system (slight fatty accumulation in Kupffer cells). Statistical evaluation of incidence data for hepatic, respiratory, and immune effects (conducted for this report) showed no difference between exposed and control rats after 2 weeks of exposure. In addition, no hepatic effects were observed in a 90-day study in rats exposed up to 4,000 ppm of trans-1,2-dichloroethene (DuPont 1998). Given the low number of animals in each group (n=6), omission of test substance purity, and lack of statistical significance, findings in the Freundt et al. (1977) study are not considered reliable to serve as the basis of the MRL.

The study by Hurtt et al. (1993) was designed to evaluate developmental effects following gestational exposure of pregnant rats to 0, 2,000, 6,000, or 12,000 ppm of trans-1,2-dichloroethene on GDs 7–16 (see details below). Dams were evaluated for signs of clinical toxicity and developmental outcomes. NOAEL and LOAEL values for effects observed in this study are summarized Table A-1. The most sensitive effect observed in the Hurtt et al. (1993) study is an ocular irritation effect (lacrimation), with a LOAEL of 2,000 ppm; a NOAEL was not identified. Therefore, lacrimation was selected as the critical effect for acute-duration exposure. Data for lacrimation are summarized in Table A-2. Note that for systemic effects (e.g., effects resulting from absorbed trans-1,2-dichloroethene), the most sensitive effect is increased resorption, with NOAEL and LOAEL values of 2,000 and 6,000 ppm, respectively. Early resorptions per litter were increased (p≤0.05) in the 6,000 and 12,000 ppm groups relative to concurrent controls; resorption data also showed a statistically significant trend across exposure concentrations. The study authors did not consider the increase in resorptions to be biologically significant because the resorption rate in concurrent controls (0.3/litter) was below historical controls for the performing laboratory for the previous 2 years (0.6–1.5/litter) and the resorption rates in treatment groups (0.6–1.1/litter) were within the recent historical control range. Given the higher LOAEL value for resorptions (compared to lacrimation) and the uncertainty regarding the biological significance of the increased resorptions per litter relative to concurrent controls but not the recent historical controls, these data would not be considered adequate to serve as the basis for an MRL. However, due to the potential for developmental toxicity at concentrations >2,000 ppm, concentrations higher than 2,000 ppm are not considered for development of the acute-duration inhalation MRL.

Table A-1 Summary of Effects Observed in Pregnant Rats Exposed to Inhaled trans-1,2-Dichloroethene on GDs 7–16

System | Effect | NOAEL/LOAEL (ppm)
System | Effect | NOAEL | LOAEL
Ocular | Lacrimation | ND | 2,000
Developmental | Increased resorptions | 2,000 | 6,000
Developmental | Decreased fetal body weight (females) | 6,000 | 12,000
Neurological | Lethargy | 6,000 | 12,000
Body weight | Decreased maternal body weight GDs 7–16 | 6,000 | 12,000

GD = gestational day; LOAEL = lowest-observed-adverse-effect level; ND = not determined; NOAEL = no-observed-adverse-effect level

Source: Hurtt et al. 1993

Table A-2 Incidence Data for Lacrimation and Resorptions Observed in Female Rats Exposed to trans-1,2-Dichloroethene on GDs 7–16

Effect | Concentration (ppm)
Effect | 0 | 2,000 | 6,000 | 12,000
Incidence of lacrimation^a,b^ | 0/24 | 13/24^c^ | 22/24^c^ | 24/24^c^
Resorptions per litter^d^ | 0.3 | 0.6 | 0.8^e^ | 1.1^e^

a Number with lacrimation/number of exposed.

b Significant trend, p≤0.0001 (Cochran-Armitage test conducted for this report).

c Significantly different from control values, p≤0.0001 (Fisher’s exact test conducted for this report).

d Significant trend, p≤0.05 (Cochran-Armitage test, as reported by Hurtt et al. 1993).

e Significantly different from control values, p≤0.05 (Fisher’s exact test, as reported by Hurtt et al. 1993). GD = gestation day

Source: Hurtt et al. 1993

Selection of the Principal Study: As discussed under Selection of the Critical Effect, Hurtt et al. (1993), a study designed to evaluate developmental effects, provides data that are suitable for derivation of the MRL. Data provided by other studies are not adequate for derivation of the MRL.

Summary of the Principal Study:

Hurtt ME, Valentine R, Alvarez L. 1993. Developmental toxicity of inhaled trans-1,2-dichloroethylene in the rat. Fundam Appl Toxicol 20(2):225–230.8449394

Groups of 24 pregnant Crl:CD BR rats were exposed to nominal concentrations of 0, 2,000, 6,000, or 12,000 ppm of trans-1,2-dichloroethene (99.64%) vapor in air for 6 hours/day (whole-body inhalation) on GDs 7–16. The post-exposure period consisted of GDs 17–22. The dams (n=24) and fetuses were sacrificed on GD 22. Mean daily chamber concentrations (data not shown) were within ±5% of nominal concentrations. The following endpoints were assessed in dams: number of pregnant rats; lethality; maternal body weight on GDs 1, 7–17, and 22 and feed consumption on GDs 1–19 and 22; clinical signs of toxicity twice daily prior to and following exposures; liver and uterus weights (GD 22); and numbers of resorptions and corpora lutea (GD 22). The following assessments were conducted in fetuses: number of live and dead fetuses; number of males and females per litter; fetal weight; and external, internal, and skeletal malformations and variations.

No maternal deaths occurred. At the end of the exposure period (GD 16), maternal weight was decreased by 33% in rats exposed to 12,000 ppm, compared to controls. However, on GD 22, body weight in the 12,000 ppm group was similar to controls. Over the exposure period (GDs 7–17), maternal feed consumption was decreased by 12 and 16% in the 6,000 and 12,000 ppm groups, respectively. For clinical signs of toxicity, lacrimation was increased at all exposure levels relative to control during the exposure period (GDs 7–16) (see Table A-3); a significant trend across exposure levels was also observed. No lacrimation was observed during the post-exposure period (GDs 17–22). Brown, periocular staining, due to excessive lacrimation, was observed in the control (1/24), 2,000 (3/24), 6,000 (18/24), and 12,000 ppm (22/24) exposure groups, and it too resolved promptly following exposure. Lethargy was observed in 10/24 dams exposed to 12,000 ppm. The study authors noted that clinical signs of central nervous system depression (incoordination immediately following exposure) were observed in the 6,000 and 12,000 ppm groups, although incidence data were not reported; therefore, NOAEL and LOAEL values could not be determined for central nervous system depression. During the post-exposure period (GDs 17–22), combined incidences of alopecia and periocular staining were increased in the 6,000 (8/24) and 12,000 ppm (11/24) groups. Resorptions per litter were increased (p≤0.05) in the 6,000 and 12,000 ppm groups relative to concurrent controls (see Table A-3); as discussed above (Selection of the Critical Effect), there is uncertainty regarding the biological significance of the resorptions per litter relative to historical controls. Mean female fetal weight was decreased by 5.9%, compared to controls, at 12,000 ppm; no effect on mean male fetal weight was observed. No fetal external, internal, or skeletal malformations or variations were observed at any exposure level.

Selection of the Point of Departure for the MRL: The BMCL_10_ of 256.47 ppm for lacrimation was selected as the basis of the acute-duration inhalation MRL.

Benchmark dose (BMD) modeling was conducted to identify a point of departure (POD) using the incidence data for lacrimation in pregnant rats exposed to trans-1,2-dichloroethene for 6 hours/day on GDs 7–16 (Hurtt et al. 1993). The data were fit to all available dichotomous models in EPA’s Benchmark Dose Software (BMDS; version 3.2) using a benchmark response (BMR) with 10% extra risk. Adequate model fit is judged by four criteria: chi-squared goodness-of-fit (p>0.1), visual inspection of the dose-response curve, BMCL (95% lower confidence limit on the benchmark response concentration [BMC]) that is not 10 times lower than the lowest non-zero concentration, and scaled residual at the data point (except the control) closest to the predefined BMR. Adequate fit to the data was observed for the Dichotomous Hill, Log-Logistic, and Log-Probit models. Inadequate fit to the data was observed for the Gamma, Multistage, and Weibull models based on BMCLs ≥10 times lower than the lowest non-zero concentration and for the Logistic and Probit models based on chi-squared goodness-of-fit p-values <0.1. Among models providing adequate fit, the lowest BMCL_10_ was selected as the POD when the difference between the BMCL_10_ values estimated from these models was ≥3 fold; otherwise, the BMCL_10_ from the model with the lowest Akaike Information Criterion (AIC) was chosen. In accordance with these selection criteria, the Log-Logistic model, a frequentist, unrestricted model, provided the best fit, with the lowest BMCL_10_ of 256.47 ppm (Table A-3). The Log-Logistic model fit is shown in Figure A-1.

Table A-3 BMD Constant Variance Model Predictions for Lacrimation in Pregnant Crl:CD BR Rats Exposed to trans-1,2-Dichloroethene 6 Hours/Day on GDs 7–16 (Hurtt et al. 1993)

Model | BMC_10_^a^ (ppm) | BMCL_10_^a^ (ppm) | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMC_10_^a^ (ppm) | BMCL_10_^a^ (ppm) | p-Value^b^ | AIC | Dose below BMC | Dose above BMC
Dichotomous Hill | 740.277 | 256.469 | 0.479 | 53.667 | −0.001 | −0.001
Gamma^d^ | 371.821 | 189.742 | 0.709 | 53.103 | −0.001 | −0.001
Log-Logistic ^e^ ^,^ ^f^ | 740.279 | 256.470 | 0.778 | 51.667 | −0.001 | −0.001
Multistage Degree 3^g^ | 281.357 | 191.599 | 0.835 | 52.936 | −0.001 | −0.001
Multistage Degree 2^g^ | 295.758 | 190.767 | 0.956 | 51.010 | −0.001 | −0.001
Multistage Degree 1^g^ | 253.774 | 188.209 | 0.898 | 51.252 | −0.001 | −0.001
Weibull^d^ | 344.544 | 190.057 | 0.722 | 53.076 | −0.001 | −0.001
Logistic | 839.119 | 589.146 | 0.047 | 58.780 | −1.583 | −1.583
Log-Probit | 698.499 | 230.591 | 0.571 | 53.379 | −0.001 | −0.001
Probit | 839.333 | 607.962 | 0.045 | 58.926 | −1.547 | −1.547

a BMC and BMCLs values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the BMC.

d Power restricted to ≥1.

e Slope restricted to ≥1.

f Selected model. BMCLs for models providing adequate fit differed by <3-fold; therefore, the model with the lowest AIC was selected (Log-Logistic).

g Betas restricted to ≥0.

AIC = Akaike Information Criterion; BMC = benchmark concentration (maximum likelihood estimate of the concentration associated with the selected benchmark response); BMCL_10_ = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., 10 = dose associated with 10% extra risk; GD = gestation day

Figure A-1 Fit of Log-Logistic Model to Incidence of Lacrimation in Pregnant Crl:CD BR Rats Exposed to trans-1,2-Dichloroethene 6 Hours/Day on Gestation Days 7–16 (Hurtt et al. 1993)

Calculations

Adjustment for Intermittent Exposure: Not applicable. The critical effect (lacrimation) is related to the concentration of trans-1,2-dichloroethene in air; therefore, no adjustment was made to a continuous 24-hour exposure.

Human Equivalent Concentration: Not applicable. The critical effect (lacrimation) is related to the concentration of trans-1,2-dichloroethene in air and does not depend upon absorption into the body.

Uncertainty Factor: The BMCL_10_ is divided by a total uncertainty factor of 100:

- 10 for extrapolation from animals to humans
- 10 for human variability
  MRL = BMCL_10_ ÷ UFs 256.47 ppm ÷ (10 x 10) = 2.6 ppm ≈ 3 ppm

Other Additional Studies or Pertinent Information that Lend Support to this MRL: An experimental study in two human subjects reported slight burning of the eyes during exposure to trans-1,2-dichloroethene concentrations of 950 ppm after 5 minutes, 1,200 ppm after 10 minutes, and 1,000 ppm for 30 minutes (Lehmann and Schmidt-Kehl 1936). No eye irritation was noted following exposure to 275 ppm for 5 minutes or 825 ppm for 10 minutes; 1,000 ppm was the only concentration tested for 30 minutes. The dose-response relationship for ocular irritation is uncertain as only two subjects were tested, purity of the test substance was not reported, and precision of methods used to measure trans-1,2-dichloroethene concentrations has not been established. However, these results indicate that humans exposed to trans-1,2-dichloroethene vapor in the air develop eye irritation at concentrations as low as 950 ppm. In laboratory animals, instillation of 0.01 mL trans-1,2-dichloroethene to the eyes of rabbits for 20 seconds resulted in ocular irritation, transient severe corneal opacity, moderate iritis, and conjunctivitis (DuPont 1988c), demonstrating clear evidence that trans-1,2-dichloroethene is an eye irritant and corroborating the selection of lacrimation as a suitable endpoint to derive the acute-duration inhalation MRL.

Agency Contacts (Chemical Manager): Malcolm Williams

## trans-1,2-Dichloroethene Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | trans-1,2-Dichloroethene
CAS Numbers: | 156-60-5
Date: | April 2025
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL for trans-1,2-dichloroethene.

Rationale for Not Deriving an MRL: Few studies have assessed the adverse effects of intermediate-duration inhalation exposure to trans-1,2-dichloroethene (DuPont 1998; Freundt et al. 1977). DuPont (1998) did not find any adverse effect in male and female rats (15/group/sex) exposed to concentrations up to 4,000 ppm (6 hours/day, 5 days/week) for 90 days. This study examined comprehensive toxicological endpoints, including histopathologic assessments. Since the DuPont (1998) study did not find adverse effects, it cannot serve as the basis for an intermediate-duration inhalation MRL for trans-1,2-dichloroethene.

The Freundt et al. (1977) study found histological changes to the respiratory tract (capillary hyperemia and alveolar distention), liver (slight fatty accumulation of liver lobules), and immune system (slight fatty accumulation in Kupffer cells) in female rats (n=6) exposed to 200 ppm (8 hours/day, 5 days/week) for 8 or 16 weeks. However, these findings were not corroborated by the DuPont (1998) study at a much higher exposure level (4,000 ppm). In addition, Freundt et al. (1977) has several weaknesses: purity of the test substance was not reported so that potential for contaminants in the test substance was not assessed; a small number of animals (n=6) were exposed; and statistical evaluation of the histological data was not presented. Given these weaknesses and lack of corroborating data, findings in this study are not considered reliable.

Agency Contacts (Chemical Manager): Malcolm Williams

## trans-1,2-Dichloroethene Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | trans-1,2-Dichloroethene
CAS Numbers: | 156-60-5
Date: | April 2025
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL for trans-1,2-dichloroethene.

Rationale for Not Deriving an MRL: No chronic-duration inhalation studies in humans or animals were identified.

Agency Contacts (Chemical Manager): Malcolm Williams

## trans-1,2-Dichloroethene Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | trans-1,2-Dichloroethene
CAS Numbers: | 156-60-5
Date: | April 2025
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL for trans-1,2-dichloroethene.

Rationale for Not Deriving an MRL: The database of studies evaluating acute-duration oral exposure to trans-1,2-dichloroethene in laboratory animals consists of single-dose, acute lethality studies (Barnes et al. 1985; Hayes et al. 1987; Munson et al. 1982) and repeated-dose studies that did not observe toxicologically significant adverse effects (Barnes et al. 1985; Munson et al. 1982; NTP 2002; Shopp et al. 1985). Acute-duration lethality studies, designed to estimate LD_50_ values, did not report adverse effects at sublethal levels. The only effects observed in repeated-dose studies were decreased fibrinogen levels (12%) and prothrombin time (7%) in male mice administered 210 mg/kg/day by gavage for 14 days (Barnes et al. 1985). However, these results are clinically inconsistent. Decreased fibrinogen would be expected to increase prothrombin time (e.g., longer time to formation of fibrinogen clot); however, prothrombin time was decreased. Therefore, the toxicological significance of these findings is uncertain. No adverse hematopoietic or hepatic effects were observed in male and female rats exposed to 5,591 and 4,500 mg/kg/day, respectively, for 5 days (NTP 2002). Munson et al. (1982) did not observe adverse hematological (including fibrinogen levels and prothrombin time), hepatic, or immunological (humoral and cellular immunity) effects in male mice exposed to 220 mg/kg/day for 20 days. No effects on humoral and cellular immune function were observed in male mice exposed to 210 mg/kg/day for 14 days (Shopp et al. 1985). Therefore, available data are not adequate to derive an acute-duration oral MRL for trans-1,2-dichloroethene.

Agency Contacts (Chemical Manager): Malcolm Williams

## trans-1,2-Dichloroethene Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | trans-1,2-Dichloroethene
CAS Numbers: | 156-60-5
Date: | April 2025
Profile Status: | Final
Route: | Oral
Duration: | Intermediate
MRL: | 0.2 mg/kg/day
Critical Effect: | Decreased humoral immunity
Reference: | Shopp et al. 1985
Point of Departure: | BMDL_1SD_ of 16.75 mg/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 13
Species: | Mouse

MRL Summary: An intermediate-duration oral MRL of 0.2 mg/kg/day was derived for trans-1,2-dichloroethene based on decreased humoral immunity in male mice exposed to trans-1,2-dichloro-ethene in drinking water for 90 days. The MRL is based on a BMDL_1SD_ of 16.75 mg/kg/day and a total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

Selection of the Critical Effect: Several studies have evaluated the toxicity of intermediate-duration oral exposure of laboratory animals to trans-1,2-dichloroethene. Reliable NOAEL and LOAEL values are summarized in Table A-4.

Table A-4 Summary of Effects Observed in Laboratory Animals Exposed to Oral trans-1,2-Dichloroethene for Intermediate Durations

Species | Duration (Route) | NOAEL/LOAEL (mg/kg/day) | | Effect | Reference
Species | Duration (Route) | NOAEL | LOAEL | Effect | Reference
Mice; (CD-1) | 90 days; (W) | ND (M); ND (F) | 17 (M); 23 (F) | Increased serum glucose | Barnes et al. 1985
Mice; (CD-1) | 90 days; (W) | 17 (M); 452 (F) | 175 (M); ND (F) | Decreased humoral immunity | Shopp et al. 1985
Rats; (F-344) | 14 weeks; (diet) | 190 (M); 780 (F) | 380 (M); 1,580 (F) | Decreased erythrocyte counts | NTP 2002
Mice; (B6C3F1) | 14 weeks; (diet) | 8,065 (M); 3,760 (F) | ND (M); 7,925 (F) | Decreased terminal body weight | NTP 2002
Rats; (Sprague-Dawley) | 14 weeks; (W) | 3,114 (M); 2,809 (F) | ND (M); ND (F) | No effects observed^a^ | Hayes et al. 1987

a Evaluations conducted in this study were lethality, body weight, hematological, hepatic, renal, and reproductive endpoints; serum glucose was also assessed.

F = female(s); LOAEL = lowest-observed-adverse-effect level; M = male(s); ND = not determined; NOAEL = no-observed-adverse-effect level; W = drinking water

The lowest LOAEL observed in intermediate-duration oral studies is 17 mg/kg/day for increased serum glucose in male mice exposed for 90 days, although the increase did not exhibit dose-dependence (Barnes et al. 1985). Compared to controls, serum glucose was increased by 27, 20, and 24% at doses of 17, 175, and 387 mg/kg/day, respectively. Similar non-dose-dependent increases were observed in females; at doses of 23, 224, and 452 mg/kg/day, serum glucose was increased by 28, 20, and 28%, respectively. In contrast to these findings, no effects on glucose levels were observed in male or female rats at doses up to 3,114 and 2,809 mg/kg/day, respectively, in another study (Hayes et al. 1987). Given the lack of a dose-response and that no effects on glucose levels were observed at much higher oral doses in the study by Hayes et al. (1987), the possible relationship between exposure to trans-1,2-dichloroethene and serum glucose levels is uncertain. Therefore, decreased serum glucose was not selected as the critical effect for derivation of the intermediate-duration oral MRL.

The next lowest LOAEL is 175 mg/kg/day for decreased humoral immunity in male mice exposed to trans-1,2-dicloroethene in drinking water for 90 days (Shopp et al. 1985). Suppression in humoral immunity in male mice, as measured by reductions in spleen AFCs directed against sRBCs, was observed at all doses tested in a dose-dependent manner; decreases were 6.9, 26.1, and 26.4% at doses of 17, 175, and 387 mg/kg/day, respectively. Other tests of immune function (spleen cell response to B cell mitogen lipopolysaccharide and hemagglutination titers) did not show suppression of humoral immunity. However, the sRBC AFC response is considered the “gold standard” for evaluating T-cell-dependent antibody responses and is considered one of the best predictors of immunotoxicity in mice (Ladics 2007). Note that conclusions made by Shopp et al. (1985) regarding trans-1,2-dichloroethene-induced humoral immune suppression are conflicting. In the study abstract, the study authors concluded that, “a marked suppression in humoral immune status was observed in male mice exposed to all three levels of DCE, as indicated by a decreased ability of spleen cells to produce antibody against sheep erythrocytes (sRBC).” In contrast, the discussion section of the paper states that, “there were some immunological changes that occurred following 90 days of exposure to the compound in the drinking water. IgM AFC was significantly decreased at all dose levels. This decrease was not severe enough to depress the functional ability of the humoral immune system, as evidenced by normal hemagglutination titers and spleen cell response to LPS.” ATSDR considers the dose-related decrease in humoral immunity based on the sRBC assay to be an appropriate critical effect for derivation of the intermediate-duration oral MRL and is a biologically relevant effect to human health. ATSDR’s conclusions are supported by the EPA Integrated Risk Information System (IRIS) derivation of the reference dose (RfD) for trans-1,2-dichloroethane(IRIS 2010b). EPA “evaluated the findings from Shopp et al. (1985) and determined, in contrast to the study authors, that suppression in the number of AFCs in male CD-1 mice represents functional suppression of the humoral immune system and not general toxicity.” Furthermore, EPA states that, “serum anti-sRBC IgM values are a general measure of the antibody response because these values reflect antibodies produced from multiple sources, including spleen, lymph nodes, and bone marrow. Therefore, the AFC assay is not expected to provide evidence of chemical immunosuppression at the level of splenic antibody production that might not be identified by measurements of serum levels of anti-sRBC IgM.”

Other intermediate-duration oral studies identified higher LOAELs than the LOAEL for decreased humoral immunity (175 mg/kg/day). NTP (2002) identified a LOAEL of 380 mg/kg/day in male rats for mild decreases in erythrocyte counts (3.1–7.1%) and a LOAEL of 7,925 mg/kg/day in female rats for a 10.7% decrease in terminal body weight. Hayes et al. (1987) did not observe any adverse effects at doses up to 3,114 and 2,809 mg/kg/day in male and female rats, respectively, via drinking water for 90 days. Therefore, decreased humoral immunity, with a LOAEL of 175 mg/kg/day identified from the Shopp et al. (1985) study, was selected as the critical effect for derivation of the intermediate-duration oral MRL for trans-1,2-dichhloroethene. This selection was made based on the following: the critical effect for the Shopp et al. (1985) study produced the lowest LOAEL (i.e., is the most sensitive) for endpoints exhibiting dose-responses, is an endpoint suitable for evaluation of immunotoxicity, and is relevant for human health.

Selection of the Principal Study: As summarized in Table A-4, the lowest LOAELs observed in intermediate-duration oral studies were 17 mg/kg/day for increased serum glucose in male mice exposed for 90 days (Barnes et al. 1985) and 175 mg/kg/day for decreased humoral immunity in male mice (Shopp et al. 1985). As discussed above, the possible relationship between exposure to trans-1,2-dichloroethene and serum glucose levels is uncertain, and effects on serum glucose were not corroborated at much higher doses (Hayes et al. 1987). Other studies either observed effects at doses >175 mg/kg/day or did not identify effects at the highest doses tested (Hayes et al. 1987; NTP 2002). Therefore, the Shopp et al. (1985) study was selected as the principal study for the MRL.

Summary of the Principal Study:

Shopp GM Jr, Sanders VM, White KL, 1985. Humoral and cell-mediated immune status of mice exposed to trans-1,2-dichloroethylene. Drug Chem Toxicol 8:393–407.4064950

Male and female mice were exposed to trans-1,2-dichloroethene (98% purity) at 0, 0.1, 1.0, or 2.0 mg/mL in drinking water for 90 days; respective daily doses of 0, 17, 175, and 387 mg/kg/day in males and 0, 23, 224, and 452 mg/kg/day in females were calculated by the study authors based on body weight and water intake. As described in Barnes et al. (1985), the treatment water was prepared as a 1% solution of emulphor (a polyethoxylated vegetable oil used to stabilize volatile chemicals in aqueous solutions [Sanzgiri and Bruckner 1997]) in deionized water. The water bottles were changed every 3–4 days and <10% of the trans-1,2-dichloroethene was lost during these intervals. Immunological effects of trans-1,2-dichloroethene were evaluated in several assays. The number of animals per group varied for each assay as noted below.

Three assays were used to evaluate the humoral immune status: (1) quantitation of spleen IgM AFCs on days 4 and 5 after in vivo exposure to sRBCs (n=12 in control group and n=8 per treatment group); (2) ex vivo hemagglutination titers to sRBC (n=23 in control group and n=6–11 per treatment group); and (3) spleen cell response to the B cell mitogen lipopolysaccharide (LPS) (n=2–9 per group). Cell-mediated immunity was evaluated in three assays: (1) delayed-type hypersensitivity response to sRBC (n=16–19 per group); (2) popliteal lymph node proliferation in response to sRBC (n=11–20 per group); and (3) spleen cell response to the T cell mitogen concanavalin (ConA) (n=2–9 per group). In addition, the following were assessed: number of peritoneal exudate cells (PEC) recruited; number of PEC to adhere to plastic; chemotactic ability of the recruited cells; and phagocytic ability of the adherent cells. The functional ability of the fixed macrophages of the reticuloendothelial system was assessed by measuring the vascular clearance rate and tissue rate of 51Cr-labeled sRBC (thymus, bone marrow).

Results of the humoral immune assay for spleen IgM AFC on days 4 and 5 after in vivo exposure to sRBC showed a decreased response in male mice; this was not observed in female mice. Expressed in terms of AFC/spleen weight, the day 4 response showed a statistically significant, dose-dependent decrease in the magnitude of response at all doses and the day 5 response showed a decreased magnitude at the highest dose. Expressed in terms of AFC/10^6^ spleen cells, the day 4 response was decreased in the mid- and high-dose groups and the day 5 response was decreased at the highest dose. Although no statistically significant change in spleen weight was observed, spleen weights decreased in magnitude with increasing dose, suggesting a potential decrease in the number of spleen cells at higher doses. Due to potential variation in the total number of cells in the spleens, results expressed in terms of AFC/10^6^ spleen cells are considered more reliable than AFC/spleen weight. In addition, the response to sRBC challenge on day 4 appears to be more sensitive than on day 5. Results of this day 4 assay are summarized in Table A-5.

Table A-5 Antibody-Forming Cell Response to sRBC in Male CD-1 Mice Exposed to trans-1,2-Dichloroethene in Drinking Water for 90 Days^a^

| Dose (mg/kg/day)
| 0 | 17 | 175 | 387
AFC/10^6^ spleen cells | 2,200±125^b^ | 2,048±152 (6.9) | 1,625±136^c^ (26.1) | 1,618±226^c^ (26.4)

a Responses were observed on day 4 after in vivo exposure to sRBC.

b Mean±SE; numbers in parentheses are the percent decreased relative to control; n=12 for control group and n=8 for all other groups.

c p<0.05 versus concurrent control group.

AFC = antibody-forming cell; SE = standard error; sRBC = sheep red blood cell

Source: Shopp et al. (1985)

Selection of the Point of Departure for the MRL: The BMDL_1SD_ of 16.75 mg/kg/day for decreased humoral response was selected as the basis of the intermediate-duration oral MRL.

BMD modeling was conducted to identify the POD from incidence data for humoral response to sRBC in male mice exposed orally to trans-1,2-dichloroethene for 90 days. The data were fit to all available continuous models in EPA’s BMDS (version 3.2) using a BMR of 1 standard deviation (1SD). Adequate model fit is judged by four criteria: chi squared goodness-of-fit (p>0.1), visual inspection of the dose-response curve, BMDL (95% lower confidence limit on the BMD) that is not 10 times lower than the lowest non-zero dose, and scaled residual at the data point (except the control) closest to the predefined BMR. Among the models providing adequate fit to the data, the lowest BMDL was selected as the POD when the difference between the BMDLs estimated from these models was ≥3 fold; otherwise, the BMDL from the model with the lowest AIC was chosen. The Exponential 4 (CV-normal) model provided the best fit. The model predictions for the humoral response to sRBC are presented in Table A-6 and the fit of the selected model (Exponential 4) is presented Figure A-2. Note that the BMDL_1SD_ of 16.75 mg/kg/day is essentially identical to the empirical NOAEL of 17 mg/kg/day.

Table A-6 Results from BMD Analysis (Constant Variance) of Humoral Immune Response to Sheep Red Blood Cells in Male CD-1 Mice Exposed to trans-1,2-Dichloroethene in Drinking Water for 90 days (Shopp et al. 1985)

Model | BMD_1SD_^a^ (mg/kg/day) | BMDL_1SD_^a^ (mg/kg/day) | Test 4 p-value^b^ | AIC | Scaled residuals^c^
Model | BMD_1SD_^a^ (mg/kg/day) | BMDL_1SD_^a^ (mg/kg/day) | Test 4 p-value^b^ | AIC | Dose below BMD | Dose above BMD
Exponential 2^d^ | 284.039 | 164.570 | 0.314 | 550.161 | 0.652 | 0.625
Exponential 3^d^ | 284.051 | 164.568 | 0.314 | 550.161 | 0.652 | 0.625
Exponential 4 ^d^ ^,^ ^e^ | 77.273 | 16.752 | 0.936 | 549.849 | 0.030 | −0.016
Exponential 5^d^ | 72.786 | 16.764 | NA | 551.843 | −0.007 | 0.005
Hill^d^ | 45.978 | 13.323 | NA | 551.843 | 0.000 | 0.000
Polynomial Degree 3^d^ | 309.206 | 195.007 | 0.260 | 550.540 | 0.596 | 0.721
Polynomial Degree 2^d^ | 309.207 | 195.005 | 0.260 | 550.540 | 0.596 | 0.721
Power^d^ | 309.205 | 195.014 | 0.260 | 550.540 | 0.596 | 0.721
Linear | 309.206 | 195.005 | 0.260 | 550.540 | 0.596 | 0.721

a BMD and BMDLs values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet adequate fit.

c Scaled residuals at doses immediately below and above the BMD.

d Restricted model.

e Recommended model. The difference between the BMDLs estimated from these models was ≥3 fold, therefore the lowest BMDL_1SD_ of models with adequate fit was selected.

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _1SD_ = exposure dose associated with a 1 standard deviation change from the control); NA = not applicable, goodness-of-fit test could not be performed

Figure A-2 Fit of Exponential 4 (Constant Variance) Model to Humoral Immune Response to Sheep Red Blood Cells in Male Mice Exposed to trans-1,2-Dichloroethene in Drinking Water for 90 Days (Shopp et al. 1985)

Calculations

Adjustment for Intermittent Exposure: Not applicable.

Uncertainty Factor: The BMDL_1SD_ is divided by a total uncertainty factor of 100:

- 10 for extrapolation from animals to humans
- 10 for human variability
  MRL = BMDL_1 SD_ ÷ UFs 16.75 mg / kg / day ÷ (10 × 10) = 0.2 mg / kg / day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: The Shopp et al. (1985) study was the only intermediate-duration oral study that evaluated humoral immunity. No supporting studies were identified.

Agency Contacts (Chemical Manager): Malcolm Williams

## trans-1,2-Dichloroethene Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | trans-1,2-Dichloroethene
CAS Numbers: | 156-60-5
Date: | April 2025
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL for trans-1,2-dichloroethene.

Rationale for Not Deriving an MRL: Two epidemiological studies have investigated effects of chronic-duration oral exposure to trans-1,2-dichloroethene (Ji et al. 2016; Ruckart et al. 2013). An increased risk of gallstone disease was positively associated with trans-1,2-dichloroethene levels in adipose tissue in a case-control study of the general population (Ji et al. 2016). Results were stratified by quartiles based on the concentration of trans-1,2-dichloroethene in adipose tissue (ng/g lipid weight): Q1 12.82–721.7; Q2 721.7–1,351; Q3 1,351–2,558; and Q4 2,558–18,135. ORs were increased (p≤0.05) in Q2 (3.49; 95% CI 1.93, 6.33), Q3 (2.38; 95% CI 1.32, 4.27), and Q4 (2.48; 95% CI 1.38, 4.46), respectively, relative to Q1. In addition, the concentration of trans-1,2-dichloroethene in adipose tissue of patients with gallstone disease (mean: 1,542 ng/g lipid weight) was significantly higher (p=0.008) compared to patients without gallstone disease (mean: 1,213 ng/g lipid weight). However, concentrations of trans-1,2-dichloroethene in adipose tissue have not been correlated with blood levels or external exposure concentrations. Ruckart et al. (2013) did not find an association between exposure to trans-1,2-dichloroethene and birth defects (neural tube defects or oral cleft defects) in children born to mothers exposed during pregnancy to trans-1,2-dichloroethene in drinking water. Based on the available epidemiological studies, data are inadequate for derivation of a chronic-duration oral MRL.

No chronic-duration oral studies in animals were identified.

Agency Contacts (Chemical Manager): Malcolm Williams

## cis-1,2-Dichloroethene Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | cis-1,2-Dichloroethene
CAS Numbers: | 156-60-5
Date: | April 2025
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL for cis-1,2-dichloroethene.

Rationale for Not Deriving an MRL: No adequate acute-duration inhalation studies were identified for cis-1,2-dichloroethene. Thus, an acute-duration inhalation MRL cannot be derived.

Agency Contacts (Chemical Manager): Malcolm Williams

## cis-1,2-Dichloroethene Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | cis-1,2-Dichloroethene
CAS Numbers: | 156-60-5
Date: | April 2025
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL for cis-1,2-dichloroethene.

Rationale for Not Deriving an MRL: No intermediate-duration inhalation studies in humans or animals were identified.

Agency Contacts (Chemical Manager): Malcolm Williams

## cis-1,2-Dichloroethene Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | cis-1,2-Dichloroethene
CAS Numbers: | 156-60-5
Date: | April 2025
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL for cis-1,2-dichloroethene

Rationale for Not Deriving an MRL: No chronic-duration inhalation studies were identified.

Agency Contacts (Chemical Manager): Malcolm Williams

## cis-1,2-Dichloroethene Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | cis-1,2-Dichloroethene
CAS Numbers: | 156-60-5
Date: | April 2025
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL for cis-1,2-dichloroethene.

Rationale for Not Deriving an MRL: One study evaluating acute-duration oral exposure of cis-1,2-dichloroethene was identified (EPA/AMRL 1990; McCauley et al. 1995). In this study, male and female rats (10/sex/group) were exposed to 0, 97, 290, 970, or 1,900 mg/kg/day cis-1,2-dichloroethene in corn oil by gavage for 14 days. Effects were observed in the hematological, hepatic, and neurological systems.

Hematological effects. Assessment of hematological parameters found that hematocrit was decreased by 8–11% at doses of 290, 970, and 1,900 mg/kg/day, relative to controls, in female rats; however, no decreases were observed for erythrocyte count or hemoglobin concentration. The toxicological significance of decreased hematocrit in the absence of decreased erythrocyte counts and hemoglobin is uncertain. No hematological effects were observed in males administered up to 1,900 mg/kg/day for 14 days.

Hepatic effects. No histopathological findings were observed in the liver in male or female rats. Increases in relative liver weights were observed in both males and females and ranged from 15% at 97 mg/kg/day to 38% at 1,900 mg/kg/day. In addition, cholesterol was increased by 40% in female, but not in male, rats at the highest dose tested of 1,900 mg/kg/day. However, given the absence of histopathological changes or changes in serum liver enzymes (e.g., AP, ALT, AST), the toxicological significance of increased relative liver weights and cholesterol cannot be determined.

Neurological effects. Clinical signs of neurotoxicity (lethargy and ataxia) were observed in the “high dose groups;” however, NOAEL and LOAEL values could not be determined because incidence data were not reported. No histopathological findings were observed in brain tissue.

Results of the 14-day oral study by EPA/AMRL (1990), and McCauley et al. (1995) do not provide suitable data to derive an acute-duration oral MRL for cis-1,2-dichloroethene.

Agency Contacts (Chemical Manager): Malcolm Williams

## cis-1,2-Dichloroethene Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | cis-1,2-Dichloroethene
CAS Numbers: | 156-60-5
Date: | April 2025
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration oral MRL for cis-1,2-dichloroethene.

Rationale for Not Deriving an MRL: One study evaluating intermediate-duration oral exposure of cis-1,2-dichloroethene was identified (EPA/AMRL 1990; McCauley et al. 1995). In this study, male and female rats (10/sex/group) were exposed to 0, 32, 97, 290, or 870 mg/kg/day cis-1,2-dichloroethene in corn oil by gavage for 90 days. Body weight and hematological effects were observed with treatment.

Body weight effects. At the highest dose tested, body weight gain over the 90-day exposure period in male rats was decreased by 37%, compared to controls. However, terminal body weight in this group was similar to terminal body weight of the control group. Therefore, the decrease in body weight gain does not appear to be toxicologically significant. No treatment-related effects on body weight gain or terminal body weight were observed in female rats.

Hematological effects. Hematocrit and hemoglobin concentration were decreased in male and female rats. In male rats, hematocrit was decreased by 5.8, 8.9, and 8.9% at doses of 290, 970, and 1,900 mg/kg/day, respectively, and hemoglobin concentration was decreased by 6.0% at doses of 970 and 1,900 mg/kg/day. No effects on erythrocyte count were observed. In female rats, hematocrit was decreased by 9.9 and 6.5% at doses of 290 and 870 mg/kg/day, respectively; erythrocyte counts and hemoglobin concentration were decreased by 5.9 and 3.9%, respectively, in the 290 mg/kg/day group, but not in the 870 mg/kg/day group, indicating that these changes were not related to treatment with cis-1,2-dichloroethene. The toxicological significance of decreased hematocrit and hemoglobin concentration in the absence of decreased erythrocyte count is uncertain.

Based on the results of the EPA/AMRL (1990), and McCauley et al. (1995) study, data are not adequate for derivation of an intermediate-duration oral MRL for cis-1,2-dichloroethene.

Agency Contacts (Chemical Manager): Malcolm Williams

## cis-1,2-Dichloroethene Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | cis-1,2-Dichloroethene
CAS Numbers: | 156-60-5
Date: | April 2025
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL for cis-1,2-dichloroethene

Rationale for Not Deriving an MRL: No chronic-duration oral studies in humans or animals were identified.

Agency Contacts (Chemical Manager): Malcolm Williams