# CHAPTER 8 REFERENCES

Albano E, Poli G, Tomasi A, 1984. Toxicity of 1,2-dibromoethane in isolated hepatocytes: role of lipid peroxidation. Chem Biol Interact 50(3):255–265.6378412
Alumot E, Nachtomi E, Mandel E, 1976. Tolerance and acceptable daily intake of chlorinated fumigants in the rat diet. Food Cosmet Toxicol 14(2):105–110. 10.1016/S0015-6264(76)80252-0.1270030
Al-Zahrani SM, Aljodai AM, Wagialla KM. 2001. Modelling and simulation of 1,2-dichloroethane production by ethylene oxychlorination in fluidized-bed reactor. Chem Eng Sci 56(2):621–626. 10.1016/s0009-2509(00)00268-2.
Andelman JB. 1985. Inhalation exposure in the home to volatile organic contaminants of drinking water. Sci Total Environ 47:443–460. 10.1016/0048-9697(85)90349-3.4089611
Anders MW, Livesey JC. 1980. Metabolism of 1,2-dihaloethanes. In: Ames B, Infante P, Reitz R, eds. Ethylene dichloride: A potential health risk? Cold Spring Harbor, NY: Cold Spring Harbor Laboratory, 331–341.
Ansari GA, Gan JC, Barton BK. 1988. Synergistic inactivation of plasma alpha 1-proteinase inhibitor by aldehydes of cigarette smoke with styrene oxide and 1,2-dichloroethane. Arch Environ Contam Toxicol 17(4):533–536.3261575
Ansari GA, Singh SV, Gan JC, 1987. Human erythrocyte glutathione S-transferase: a possible marker of chemical exposure. Toxicol Lett 37(1):57–62.3296321
API. 2008. The environmental behavior of ethylene dibromide and 1,2-dichloroethane in surface water, soil, and groundwater. American Petroleum Institute. API Publication 4774.
Aragno M, Tamagno E, Danni O, 1992. In vivo studies on halogen compound interactions. III. Effect of carbon tetrachloride plus 1,2-dichloroethane on liver necrosis and fatty accumulation. Res Commun Chem Pathol Pharmacol 76(3):341–354.1636056
Armstrong MJ, Galloway SM. 1993. Micronuclei induced in peripheral blood of Eu-PIM-1 transgenic mice by chronic oral treatment with 2-acetylaminofluorene or benzene but not with diethyl-nitrosamine or 1,2-dichloroethane. Mutat Res 302(1):61–70.7683108
Arnts RR, Seila RL, Bufalini JJ. 1989. Determination of room temperature OH rate constants for acetylene, ethylene dichloride, ethylene dibromide, p-dichlorobenzene and carbon disulfide. JAPCA 39(4):453–460. 10.1080/08940630.1989.10466544.
ASTSWMO. 2014. Lead scavengers survey report. Washington, DC: Association of State and Territorial Solid Waste Management Officials. https://astswmo.org/files/policies/Tanks/2014-08-ASTSWMOLeadScavengersReport-FINAL.pdf. February 13, 2023.
Atkinson R. 1986. Kinetics and mechanisms of the gas-phase reactions of the hydroxyl radical with organic compounds. Chem Rev 86(1):69–201. 10.1021/cr00071a004.
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; notice. Agency for Toxic Substances and Disease Registry. Fed Regist 54(174):37618–37634.
ATSDR. 2022. 1,2-Dichloroethane. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/SPL/resources/index.html. June 1, 2023.
Austin SG, Schnatter AR. 1983a. A cohort mortality study of petrochemical workers. J Occup Med 25(4):304–312.6304270
Austin SG, Schnatter AR. 1983b. A case-control study of chemical exposures and brain tumors in petrochemical workers. J Occup Med 25(4):313–320.6854420
Baertsch A, Lutz WK, Schlatter C. 1991. Effect of inhalation exposure regimen on DNA binding potency of 1,2-dichloroethane in the rat. Arch Toxicol 65(3):169–176.2053843
Ballering LA, Nivard MJ, Vogel EW. 1993. Characterization of the genotoxic action of three structurally related 1,2-dihaloalkanes in Drosophila melanogaster. Mutat Res 285(2):209–217.7678893
Ballering LA, Nivard MJ, Vogel EW. 1994. Mutation spectra of 1,2-dibromoethane, 1,2-dichloroethane and 1-bromo-2-chloroethane in excision repair proficient and repair deficient strains of Drosophila melanogaster. Carcinogenesis 15(5):869–875. 10.1093/carcin/15.5.869.8200089
Banerjee S. 1988. DNA damage in rodent liver by 1,2-dichloroethane, a hepatocarcinogen. Cancer Biochem Biophys 10(2):165–173.2472872
Banerjee S, Van Duuren BL. 1979. Binding of carcinogenic halogenated hydrocarbons to cell macromolecules. J Natl Cancer Inst 63(3):707–711. 10.1093/jnci/63.3.707.381753
Banerjee S, Baughman GL. 1991. Bioconcentration factors and lipid solubility. Environ Sci Technol 25(3):536–539. 10.1021/es00015a024.
Banerjee S, Van Duuren BL, Oruambo FI. 1980. Microsome-mediated covalent binding of 1,2-dichloroethane to lung microsomal protein and salmon sperm DNA. Cancer Res 40(7):2170–2173.7388783
Barbash JE, Reinhard M. 1989. Abiotic dehalogenation of 1,2-dichloroethane and 1,2-dibromoethane in aqueous solution containing hydrogen sulfide. Environ Sci Technol 23(11):1349–1358. 10.1021/es00069a004.
Barbee GC. 1994. Fate of chlorinated aliphatic hydrocarbons in the vadose zone and ground water. Ground Water Monit Remediat 14(1):129–140. 10.1111/j.1745-6592.1994.tb00098.x.
Barber ED, Donish WH, Mueller KR. 1981. A procedure for the quantitative measurement of the mutagenicity of volatile liquids in the Ames Salmonella/microsome assay. Mutat Res 90(1):31–48.7029269
Barkley J, Bunch J, Bursey JT, 1980. Gas chromatography mass spectrometry computer analysis of volatile halogenated hydrocarbons in man and his envi–nment--A multimedia environmental study. Biomed Mass Spectrom 7(4):139–147.7448328
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486.3222488
Benson LO, Teta MJ. 1993. Mortality due to pancreatic and lymphopoietic cancers in chlorohydrin production workers. Br J Ind Med 50:710–716.8398857
Bianchi AP, Varney MS, Phillips J. 1991. Analysis of volatile organic compounds in estuarine sediments using dynamic headspace and gas chromatography—mass spectrometry. J Chromatogr A 542:413–450. 10.1016/s0021-9673(01)88779-3.
Blount BC, Kobelski RJ, McElprang DO, 2006. Quantification of 31 volatile organic compounds in whole blood using solid-phase microextraction and gas chromatography–mass spectrometry. J Chromatogr Sci B 832(2):292–301.
Borisover MD, Graber ER. 1997. Specific interactions of organic compounds with soil organic carbon. Chemosphere 34(8):1761–1776. 10.1016/s0045-6535(97)00032-5.
Bosma TN P, van Aalst-van Leewen M, Geritse J, 1998. Intrinsic dechlorination of 1,2-dichloroethane at an industrial site. In: Wickramanayake GB, Hinchee RE, eds. N170mbryogenestuation: Chlorinated and recalcitrant compounds. Columbus, OH: Battelle Press, 7–11.
Bove FJ. 1996. Public drinking water contamination and birthweight, prematurity, fetal deaths, and birth defects. Toxicol Ind Health 12(2):255–266.8794538
Bove FJ, Fulcomer MC, Klotz JB, 1995. Public drinking water contamination and birth outcomes. Am J Epidemiol 141(9):850–862. 10.1093/oxfordjournals.aje.a117521.7717362
Boverhof DR, Hotchkiss JA, LeBaron MJ, 2018. Investigation of the potential non-genotoxic mode of action for 1,2-dichloroethane (DCE)-induced mammary tumors in female rats. Toxicol Lett 295:S150–S151.
Bowler RM, Gysens S, Hartney C. 2003. Neuropsychological effects of ethylene dichloride exposure. Neurotoxicology 24(4–5):553–562. 10.1016/S0161-813X(03)00027-5.12900069
Brem H, Stein AB, Rosenkranz HS. 1974. The mutagenicity and DNA-modifying effect of haloalkanes. Cancer Res 34(10):2576–2579.4607208
Brender JD, Shinde MU, Zhan FB, 2014. Maternal residential proximity to chlorinated solvent emissions and birth defects in offspring: a case-control study. Environ Health 13:96. 10.1186/1476-069X-13-96.25406847
Brittebo EB, Kowalski B, Ghantous H, 1989. Epithelial binding of 1,2-dichloroethane in mice. Toxicology 56(1):35–45. 10.1016/0300-483x(89)90210-2.2728005
Brondeau GR, Bonnet P, Guenier JP, 1983. Short-term inhalation test for evaluating industrial hepatotoxicants in rats. Toxicol Lett 19:139–146.6658818
Brosseau J, Heitz M. 1994. Trace gas compound emissions from municipal landfill sanitary sites. Atmos Environ 28(2):285–293. 10.1016/1352-2310(94)90103-1.
Brown HS, Bishop DR, Rowan CA. 1984. The role of skin absorption as a route of exposure for volatile organic compounds (VOCs) in drinking water. Am J Public Health 74(5):479–484. 10.2105/ajph.74.5.479.6711723
Brüggemann R, Trapp S, Matthies M. 1991. Behavior assessment of a volatile chemical in the Rhine River. Environ Toxicol Chem 10(9):1097–1103. 10.1002/etc.5620100901.
Budava’i S, O'Neil MJ, Smith A, 2013. Ethylene dichloride. In: The Merck–index - An encyclopedia of chemicals, drugs, and biologicals. Cambridge, UK: Royal Society of Chemistry, 3849.
Buijs W, van der Gen A, Mohn GR, 1984. The direct mutagenic activity of alpha, omega-dihalogenoalkanes in Salmonella typhimurium. Strong correlation between chemical properties and mutagenic activity. Mutat Res 141(1):11–14.6384769
Bundschuh I, Herbort C, Fels LM, 1993. Renal fibronectin excretion as a marker for renal environmental toxins. Contrib Nephrol 101:177–184.8467673
Burk T, Zarus G. 2013. Community exposures to chemicals through vapor intrusion: a review of past agency for toxic substances and Disease Registry public health evaluations. J Environ Health 75(9):36–41.
Canter LW, Sabatini DA. 1994. Contamination of public ground water supplies by Superfund sites. Int J Environ Stud 46(1):35–57. 10.1080/00207239408710909.
Capel PD, Larson SJ. 1995. A chemodynamic approach for estimating losses of target organic chemicals from water during sample holding time. Chemosphere 30(6):1097–1107. 10.1016/0045-6535(94)00004-e.
Casciola LA, Ivanetich KM. 1984. Metabolism of chloroethanes by rat liver nuclear cytochrome P-450. Carcinogenesis 5(5):543–548. 10.1093/carcin/5.5.543.6722974
CDC. 2018. National Health and Nutrition Examination Survey data. Volatile organic compounds and trihalomethane–/MTBE - Blood (VOCWB_I). Hyattsville, MD: Centers for Disease Control and Prevention. https://wwwn.cdc.gov/Nchs/Nhanes/2015-2016/VOCWB_I.htm. April 30, 2021.
CDPR. 2019. Output reporting for ethylene dichloride (274). California Department of Pesticide Regulation. https://apps.cdpr.ca.gov/cgi-bin/label/labq.pl?p_chem=274&activeonly=off. April 30, 2021.
Chan MH, Chen HH, Lin YR. 2002. Aliphatic chlorinated hydrocarbons alter the contractile responses of tracheal smooth muscle in piglet. J Toxicol Environ Health A 65(3–4):293–304. 10.1080/15287390252800873.11911492
Chang HL, Alvarez-Cohen L. 1996. Biodegradation of individual and multiple chlorinated aliphatic hydrocarbons by methane-oxidizing cultures. Appl Environ Microbiol 62(9):3371–3377.8795228
Charlap JH. 2015. An extended one-generation drinking water reproductive toxicity study of ethylene dichloride in rats. HAP Task Force. Submitted to the U.S. Environmental Protection Agency. WIL-417007. https://www.regulations.gov/document/EPA-HQ-OPPT-2003-0010-0134. April 30, 2021.
Cheever KL, Cholakis JM, el-Hawari AM, 1990. Ethylene dichloride: the influence of disulfiram or ethanol on oncogenicity, metabolism, and DNA covalent binding in rats. Fundam Appl Toxicol 14(2):243–261. 10.1016/0272-0590(90)90205-x.2318350
Cheh AM, Hooper AB, Skochdopole J, 1980. A comparison of the ability of frog and rat S-9 to activate promutagens in the Ames test. Environ Mutagen 2(4):487–508.7030729
Chen C, Puhakka JA, Ferguson JF. 1996. Transformations of 1,1,2,2-tetrachloroethane under methanogenic conditions. Environ Sci Technol 30(2):542–547. 10.1021/es9502987.
Chen S, Zhang Z, Lin H, 2015. 1,2-Dichloroethane-induced toxic encephalopathy: a case series with morphological investigations. J Neurol Sci 351(1–2):36–40. 10.1016/j.jns.2015.02.020.25743226
Cheng TJ, Huang ML, You NC, 1999. Abnormal liver function in workers exposed to low levels of ethylene dichloride and vinyl chloride monomer. J Occup Environ Med 41(12):1128–1133.10609234
Cheng TJ, Chou PY, Huang ML, 2000. Increased lymphocyte sister chromatid exchange frequency in workers with exposure to low level of ethylene dichloride. Mutat Res 470(2):109–114.11027964
Chiou CT, Freed VH, Peters LJ, 1980. Evaporation of solutes from water. Environ Int 3(3):231–236. 10.1016/0160-4120(80)90123-3.
Chroust K, Jowett T, Farid-Wajidi MF, 2001. Activation or detoxification of mutagenic and carcinogenic compounds in transgenic Drosophila expressing human glutathione S-transferase. Mutat Res Genet Toxicol Environ Mutagen 498(1):169–179.
Chroust K, Pavlová M, Prokop Z, 2007. Quantitative structure-activity relationships for toxicity and genotoxicity of halogenated aliphatic compounds: wing spot test of Drosophila melanogaster. Chemosphere 67(1):152–159. 10.1016/j.chemosphere.2006.09.020.17113125
Clark RM, Goodrich JA, Deininger RA. 1986. Drinking water and cancer mortality. Sci Total Environ 53(3):153–172.3764408
Class T, Ballschmiter K. 1986. Chemistry of organic traces in air. VI: Distribution of chlorinated C1-C4 hydrocarbons in air over the northern and southern Atlantic Ocean. Chemosphere 15(4):413–427. 10.1016/0045-6535(86)90535-7.
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1:111–113.3843496
Cmarik JL, Inskeep PB, Meredith MJ, 1990. Selectivity of rat and human glutathione S-transferase in activation of ethylene dibromide by glutathione conjugation and DNA binding and induction of unscheduled DNA synthesis in human hepatocytes. Cancer Res 50:2747–2752.2328501
CMR. 1998. Chemical profile: Ethylene dichloride. Chem Market Rep (February 16,1998):45.
Cohen MA, Ryan PB, Yanagisawa Y, 1989. Indoor/outdoor measurements of volatile organic compounds in the Kanawha Valley of West Virginia. JAPCA 39(8):1086–1093. 10.1080/08940630.1989.10466593.2795113
Cole RH, Frederick RE, Healy RP, 1984. Preliminary findings of the priority pollutant monitoring project of the nationwide urban runoff program. J Water Pollut Control Fed 56(7):898–908.
Conkle JP, Camp BJ, Welch BE. 1975. Trace composition of human respiratory gas. Arch Environ Health 30(6):290–295.1137435
Corapcioglu MY, Hossain MA. 1990. Ground-water contamination by high-density immiscible hydrocarbon slugs in gravity-driven gravel aquifers. Groundwater 28(3):403–412. 10.1111/j.1745-6584.1990.tb02270.x.
Cottalasso D, Domenicotti C, Traverso N, 2002. Influence of chronic ethanol consumption on toxic effects of 1,2-dichloroethane: glycolipoprotein retention and impairment of dolichol concentration in rat liver microsomes and Golgi apparatus. Toxicology 178(3):229–240. 10.1016/s0300-483x(02)00235-4.12167309
Cox EE, McMaster M, Major DW, 1998. Natural attenuation of 1,2-dichloroethane and chloroform in groundwater at a superfund site. In: Wickramanayake GB, Hinchee RE, eds. N172mbryogenestuation: Chlorinated and recalcitrant compounds. Columbus, OH: Battelle Press, 309–314.
Crebelli R, Conti G, Conti L, 1984. Induction of somatic segregation by halogenated aliphatic hydrocarbons in Aspergillus nidulans. Mutat Res 138(1):33–38.6387478
Crebelli R, Benigni R, Franekic J, 1988. Induction of chromosome malsegregation by halogenated organic solvents in Aspergillus nidulans: unspecific or specific mechanism? Mutat Res 201(2):401–411. 10.1016/0027-5107(88)90027-9.3050490
Crespi CL, Seixas GM, Turner TR, 1985. Mutagenicity of 1,2-dichloroethane and 1,2-dibromoethane in two human lymphoblastoid cell lines. Mutat Res 142(3):133–140. 10.1016/0165-7992(85)90053-3.3883141
Croen LA, Shaw GM, Sanbonmatsu L, 1997. Maternal residential proximity to hazardous waste sites and risk for selected congenital malformations. Epidemiology 8(4):347–354. 10.1097/00001648-199707000-00001.9209846
Daft JL. 1988. Rapid determination of fumigant and industrial chemical residues in food. J Assoc Off Anal Chem 71(4):748–760.3417594
Daft JL. 1991. Fumigants and related chemicals in foods: review of residue findings, contamination sources, and analytical methods. Sci Total Environ 100:501–518. 10.1016/0048-9697(91)90390-z.2063187
Dai H, Jing S, Wang H, 2017. VOC characteristics and inhalation health risks in newly renovated residences in Shanghai, China. Sci Total Environ 577:73–83. 10.1016/j.scitotenv.2016.10.071.27817926
Dang J, Chen J, Bi F, 2019. The clinical and pathological features of toxic encephalopathy caused by occupational 1,2-dichloroethane exposure. Medicine 98(17):e15273. 10.1097/MD.0000000000015273.31027082
Daniel FB, Robinson M, Olson GR, 1994. Ten and ninety-day toxicity studies of 1,2-dichloroethane in Sprague-Dawley rats. Drug Chem Toxicol 17(4):463–477. 10.3109/01480549409014312.7821233
Danni O, Aragno M, Tamagno E, 1992. In vivo studies on halogen compound interactions. IV. Interaction among different halogen derivatives with and without synergistic action on liver toxicity. Res Commun Chem Pathol Pharmacol 76(3):355–366.1636057
Dawes VJ, Waldock MJ. 1994. Measurement of volatile organic compounds at UK national monitoring plan stations. Mar Pollut Bull 28(5):291–298. 10.1016/0025-326x(94)90153-8.
Dawson BV, Johnson PD, Goldberg SJ, 1993. Cardiac teratogenesis of halogenated hydrocarbon— Contaminated drinking water. J Am Coll Cardiol 21(6):1466–1472. 10.1016/0735-1097(93)90325-u.8473657
De Wildeman S, Nollet H, Van Langenhove H, 2001. Reductive biodegradation of 1,2-dichloroethane by methanogenic granular sludge in lab-scale UASB reactors. Adv Environ Res 6(1):17–27.
DeMarini DM, Brooks HG. 1992. Induction of prophage lambda by chlorinated organics: Detection of some single-species/single-site carcinogens. Environ Mol Mutagen 19:98–111.1531793
Dilling WL. 1977. Interphase transfer processes. II. Evaporation rates of chloro methanes, ethanes, ethylenes, propanes, and propylenes from dilute aqueous solutions. Comparisons with theoretical predictions. Environ Sci Technol 11(4):405–409. 10.1021/es60127a009.
Dilling WL, Tefertiller NB, Kallos GJ. 1975. Evaporation rates and reactivities of methylene chloride, chloroform, 1,1,1-trichloroethane, trichloroethylene, tetrachloroethylene, and other chlorinated compounds in dilute aqueous solutions. Environ Sci Technol 9(9):833–838. 10.1021/es60107a008.
DOE. 2018a. Table 3: Protective action criteria (PAC) rev. 29a based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. June 2018. U.S. Department of Energy. https://edms3.energy.gov/pac/docs/Revision_29A_Table3.pdf. July 6, 2022.
DOE. 2018b. Protective action criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29A, June 2018. U.S. Department of Energy. https://edms3.energy.gov/pac/. July 6, 2022.
Doherty AT, Ellard S, Parry EM, 1996. An investigation into the activation and deactivation of chlorinated hydrocarbons to genotoxins in metabolically competent human cells. Mutagenesis 11(3):247–274. 10.1093/mutage/11.3.247.8671747
Dreher E, Beutel KK, Myers JD, 2014. Chloroethanes and chloroethylenes. In: ’llmann's encyclopedia of industrial chemistry. Weinheim, Germany: Wiley-VCH, 1–81. 10.1002/14356007.o06_o01.pu’2.
D'Souza RW, Francis WR, Andersen ME. 1988. Physiological model for tissue glutathione depletion and increased resynthesis after ethylene dichloride exposure. J Pharmacol Exp Ther 245(2):563–5’8.3367306
D'Souza R, Francis WR, Bruce RD, 1987. Physiologically based pharmacokinetic model for ethylene dichloride and its application in risk assessment. In: Pharmacokinetics in risk assessment: Drinking water and health. Vol. 8. Washington, DC: National Academy Press, 286–301.
Easley DM, Kleopfer RD, Carasea AM. 1981. Gas chromato–aphic--mass spectrometric determination of volatile organic compounds in fish. J Assoc Off Anal Chem 64(3):653–656.7240070
Elbir T, Cetin B, Cetin E, 2007. Characterization of volatile organic compounds (VOCs) and their sources in the air of Izmir, Turkey. Environ Monit Assess 133(1–3):149–160. 10.1007/s10661-006-9568-z.17180406
EPA. 1977. Monitoring to detect previously unrecognized pollutants in surface water. Washington, DC U.S. Environmental Protection Agency. EPA560677015.
EPA. 1980. Acquisition and chemical analysis of’mother's milk for selected toxic substances. Washington, DC: U.S. Environmental Protection Agency. EPA5601380029.
EPA. 1981. Engineering handbook for hazardous waste incineration. Cincinnati, OH: U.S. Environmental Protection Agency. PB81248163. SW889.
EPA. 1982. Direct measurement of volatile organic compounds in breathing-zone air, drinking water, breath, blood, and urine. Research Triangle Park, NC: U.S. Environmental Protection Agency. PB82186545. EPA600482015.
EPA. 1985. Health assessment document for 1,2-dichloroethane. Washington, DC: U.S. Environmental Protection Agency. EPA600884006F.
EPA. 1987. Atmospheric persistence of eight air toxics: Project summary. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA6008387004.
EPA. 1988. National ambient volatile organic compounds (VOCs) database update. Washington, DC: U.S. Environmental Protection Agency. PB88195631. EPA600388010.
EPA. 1989. Interaction between water pollutants: Quantitative electron microscopy of hepatic morphological changes induced by 1,2-dichloroethane (DCE) and 1,1,-dichloroethylene (VDC). Research Triangle Park, NC: U.S. Environmental Protection Agency. PB89214126. EPA600S189005.
EPA. 1991. 1990 Urban air toxics monitoring program. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA450491024.
EPA. 1992a. Superfund record of decision: Darling Hill Dump, VT. U.S. Environmental Protection Agency. PB93963702. EPARODR0192064.
EPA. 1992b. Superfund record of decision: Pacific Coast Pipeline, CA. U.S. Environmental Protection Agency. PB93964502. EPARODR092078.
EPA. 1992c. Superfund record of decision: Clare Water Supply, MI. U.S. Environmental Protection Agency. PB93964106. EPARODR0592209. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=91001NOE.txt. December 9, 2022.
EPA. 1993. A literature review of atmospheric transformation products of clean air act title III hazardous air pollutants. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA600R94088.
EPA. 1994a. Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry. Washington DC: U.S. Environmental Protection Agency. EPA600890066F.
EPA. 1994b. Method 8010B: Halogenated volatile organics by gas chromatography. U.S. Environmental Protection Agency.
EPA. 1994c. Method 8240B: Halogenated volatile organics by gas chromatography. U.S. Environmental Protection Agency.
EPA. 1996. Drinking water regulations and health advisories. Washington, DC: U.S. Environmental Protection Agency. EPA822B96002.
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. EPA260B05001.
EPA. 2009. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency. EPA816F09004. https://www.epa.gov/sites/production/files/2016-06/documents/npwdr_complete_table.pdf. August 2, 2019.
EPA. 2010. Provisional peer-reviewed toxicity values for 1,2-dichloroethane (CASRN 107–06-2). Cincinnati, OH: U.S. Environmental Protection Agency. EPA690R10011F.
EPA. 2011. Background indoor air concentrations of volatile organic compounds in North American residences (1990–2005): A compilation of statistics for assessing vapor intrusion. Washington, DC: U.S. Environmental Protection Agency. EPA530R10001.
EPA. 2012a. 2012 Chemical data reporting data. U.S. Environmental Protection Agency.
EPA. 2012b. Advances in inhalation gas dosimetry for derivation of a reference concentration (RfC) and use in risk assessment. Washington, DC: U.S. Environmental Protection Agency. EPA600R12044.
EPA. 2016. 2016 Chemical data reporting data. U.S. Environmental Protection Agency.
EPA. 2018a. Toxic chemical release inventory reporting forms and instructions: Revised 2017 Version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. EPA260B05001.
EPA. 2018b. 2014 NATA: Assessment results. Pollutant specific results: 1,2-Dichloroethane. U.S. Environmental Protection Agency. https://www.epa.gov/national-air-toxics-assessment/2014-nata-assessment-results. April 30, 2021.
EPA. 2018c. 2018 Edition of the drinking water standards and health advisories tables. U.S. Environmental Protection Agency.
EPA. 2018d. Compiled AEGL values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2018-08/documents/compiled_aegls_update_27jul2018.pdf. April 12, 2020.
EPA. 2020. Benchmark dose software (BMDS). Version 3.2 user guide. U.S. Environmental Protection Agency. EPA600R20216. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P10103T2.txt. November 14, 2023.
EPA. 2021a. Designation, reportable quantities, and notification. U.S. Environmental Protection Agency. 40 CFR 302. https://www.ecfr.gov/cgi-bin/text-idx?SID=e7ed463134bffdbe475721c16ddbb391&mc=true&node=pt40.30.302&rgn=div5. April 30, 2021.
EPA. 2021b. Land disposal restrictions. U.S. Environmental Protection Agency. 40 CFR 268. https://www.ecfr.gov/cgi-bin/text-idx?SID=aa1408f99084487a0f110ee4746e945f&mc=true&node=pt40.28.261&rgn=div5. April 30, 2021.
EPA. 2021c. Identification and listing of hazardous waste. U.S. Environmental Protection Agency. 40 CFR 261. https://www.ecfr.gov/cgi-bin/text-idx?SID=aa1408f99084487a0f110ee4746e945f&mc=true&node=pt40.28.261&rgn=div5. April 30, 2021.
EPA. 2022. Annual summary data: 1,2-dichloroethane. Air quality system: Concentration by monitor. U.S. Environmental Protection Agency. https://www.epa.gov/aqs. February 13, 2023.
Erve JC, Deinzer ML, Reed DJ. 1996. Reaction of human hemoglobin toward the alkylating agent S-(2-chloroethyl)glutathione. J Toxicol Environ Health 49(2):127–143.8874532
Farrington JW. 1991. Biogeochemical processes governing exposure and uptake of organic pollutant compounds in aquatic organisms. Environ Health Perspect 90:75–84. 10.1289/ehp.90-1519506.1904812
FDA. 2017. Sub–art B - Requirements for specific standardized beverages. Bottled water. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 165.110. https://www.gpo.gov/fdsys/pkg/CFR-2017-title21-vol2/pdf/CFR-2017-title21-vol2-sec165-110.pdf. September 7, 2017.
FDA. 2018– Q3C - Tables and list guidance for industry. Food and Drug Administration. https://www.fda.gov/media/133650/download. November 29, 2022.
FDA. 2021a. Food additives permitted for direct addition to food for human consumption. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 172. https://www.govinfo.gov/content/pkg/CFR-2021-title21-vol3/pdf/CFR-2021-title21-vol3-part172.pdf. November 29, 2022.
FDA. 2021b. Secondary direct food additives permitted in food for human consumption. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 1973. https://www.govinfo.gov/content/pkg/CFR-2021-title21-vol3/pdf/CFR-2021-title21-vol3-part173.pdf. November 29, 2022.
FDA. 2021c. Food additives permitted in feed and drinking water of animals. Ethylene dichloride. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 573.440. https://www.govinfo.gov/content/pkg/CFR-2021-title21-vol6/pdf/CFR-2021-title21-vol6-sec573-440.pdf. November 29, 2022.
FDA. 2022. Ethylene dichloride. Substances added to food. U.S. Food and Drug Administration. https://www.cfsanappsexternal.fda.gov/scripts/fdcc/index.cfm?set=FoodSubstances&id=ETHYLENEDICHLORIDE. November 28, 2022.
Ferreri AM, Rocchi P, Capucci A, 1983. Induction of diphtheria toxin-resistant mutants in human cells by halogenated compounds. Cancer Res and Clin Oncol 105:111–112.
Först C, Stieglitz L, Roth W, 1989. Quantitative analysis of volatile organic compounds in landfill leachates. Int J Environ Anal Chem 37(4):287–293. 10.1080/03067318908026905.
Fossett NG, Byrne BJ, Tucker AB, 1995. Mutation spectrum of 2-chloroethyl methanesulfonate in Drosophila melanogaster premeiotic germ cells. Mutat Res 331:213–224.7500980
Franken R, Kasiotis KM, Tsakirakis AN, 2020. Experimental assessment of inhalation and dermal exposure to chemicals during industrial or professional activities in relation to the performance of ECETOC TRA. Ann Work Expo Health 64(9):944–958. 10.1093/annweh/wxaa070.32761049
Frasch HF, Barbero AM, Alachkar H, 2007. Skin penetration and lag times of neat and aqueous diethyl phthalate, 1,2-dichloroethane and naphthalene. Cutan Ocul Toxicol 26(2):147–160. 10.1080/15569520701212274.17612981
Fusillo TV, Hochreiter JJ, Lord DG. 1985. Distribution of volatile organic compounds in a New Jersey Coastal Plain aquifer system. Groundwater 23(3):354–360. 10.1111/j.1745-6584.1985.tb00780.x.
Gajjar RM, Kasting GB. 2014. Absorption of ethanol, acetone, benzene and 1,2-dichloroethane through human skin in vitro: a test of diffusion model predictions. Toxicol Appl Pharmacol 281(1):109–117. 10.1016/j.taap.2014.09.013.25283951
Gao J, Zhang J, Li H, 2018. Comparative study of volatile organic compounds in ambient air using observed mixing ratios and initial mixing ratios taking chemical loss into account – A case study in a typical urban area in Beijing. Sci Total Environ 628–629:791–804.
Gargas ML, Burgess RJ, Voisard DE, 1989. Partition coefficients of low-molecular-weight volatile chemicals in various liquids and tissues. Toxicol Appl Pharmacol 98(1):87–99.2929023
Garrison SC, Leadingham RS. 1954. A fatal case of ethylene dichloride poisoning in an occupational therapy department of a neuropsychiatric hospital. Am J Phys Med 33(4):230–237.13180701
Giri AK, Que Hee SS. 1988. In vivo sister chromatid exchange induced by 1,2-dichloroethane on bone marrow cells of mice. Environ Mol Mutagen 12(3):331–334.3169011
Gocke E, Wild D, Eckhardt K, 1983. Mutagenicity studies with the mouse spot test. Mutat Res 117(1–2):201–212.6835259
Gold LS. 1980. Human exposures to ethylene dichloride. In: Ames BN, Infante P, Reitz R, eds. Ethylene dichloride: A potential health risk? Banbury report No. 5. Cold Harbor Spring, NY: Cold Harbor Spring Laboratory, 209–225.
Goldberg SJ, Lebowitz MD, Graver EJ, 1990. An association of human congenital cardiac malformations and drinking water contaminants. J Am Coll Cardiol 16(1):155–164. 10.1016/0735-1097(90)90473-3.2358589
Goldberg MS, Al-Homsi N, Goulet L, 1995. Incidence of cancer among persons living near a municipal solid waste landfill site in Montreal, Quebec. Arch Environ Health 50:416–424.8572719
Gonzalez FJ, Gelboin HV. 1994. Role of human cytochromes P450 in the metabolic activation of chemical carcinogens and toxins. Drug Metab Rev 26(1–2):165–183. 10.3109/03602539409029789.8082563
Guengerich FP, Kim DH, Iwasaki M. 1991. Role of human cytochrome P-450 IIE1 in the oxidation of many low molecular weight cancer suspects. Chem Res Toxicol 4(2):168–179. 10.1021/tx00020a008.1664256
Guengerich FP, Crawford WM, Domoradzki JY, 1980. In vitro activation of 1,2-dichloroethane by microsomal and cytosolic enzyme. Toxicol Appl Pharmacol 55:303–317.6999663
Guengerich FP, Peterson LA, Cmarik JL, 1987. Activation of dihaloalkanes by glutathione conjugation and formation of DNA adducts. Environ Health Perspect 76:15–18. 10.1289/ehp.877615.3329096
Hachiya N, Motohashi Y. 2000. Examination of lacZ mutant induction in the liver and testis of Muta Mouse following injection of halogenated aliphatic hydrocarbons classified as human carcinogens. Ind Health 38(2):213–220. 10.2486/indhealth.38.213.10812844
Hamza M, Tohid H, Maibach H. 2015. Shaving effects on percutaneous penetration: clinical implications. Cutan Ocul Toxicol 34(4):335–343.25363065
Hansen J. 2000. Elevated risk for male breast cancer after occupational exposure to gasoline and vehicular combustion products. Am J Ind Med 37(4):349–352.10706746
Hayes FD, Short RD, Gibson JE. 1973. Differential toxicity of monochloroacetate, monofluoroacetate and monoiodoacetate in rats. Toxicol Appl Pharmacol 26(1):93–102.4748142
Haynes WM, Lide DR, Bruno TJ, eds. 2015. 1,2-Dichloroethane. In: CRC handbook of chemistry and physics. 95th ed. Boca Raton, FL: CRC Press, 5.166.
Heavner DL, Morgan WT, Ogden MW. 1995. Determination of volatile organic compounds and ETS apportionment in 49 homes. Environ Int 21(1):3–21. 10.1016/0160-4120(94)00018-3.
Heavner DL, Morgan WT, Ogden MW. 1996. Determination of volatile organic compounds and respirable suspended particulate matter in New Jersey and Pennsylvania homes and workplaces. Environ Int 22(2):159–183. 10.1016/0160-4120(96)00003-7.
Heikes DL. 1987. Purge and trap method for determination of volatile halocarbons and carbon disulfide in table-ready foods. J Assoc Off Anal Chem 70(2):215–226.3571114
Heikes DL, Hopper ML. 1986. Purge and trap method for determination of fumigants in whole grains, milled grain products, and intermediate grain-based foods. J Assoc Off Anal Chem 69(6):990–998.3542956
Heikes DL, Jensen SR, Fleming-Jones ME. 1995. Purge and trap extraction with GC-MS determination of volatile organic compounds in table-ready foods. J Agric Food Chem 43(11):2869–2875. 10.1021/jf00059a018.
Hellman B, Brandt I. 1986. Effects of carcinogenic halogenated aliphatic hydrocarbons on [3H]thymidine incorporation into various organs of the mouse: A comparison between 1,2-dibromoethane and 1,2-dichloroethane. Mutat Res 163:193–199.3531831
Hemminki K, Falck K, Vainio H. 1980. Comparison of alkylation rates and mutagenicity of directly acting industrial and laboratory chemicals: Epoxides, glycidyl ethers, methylating and ethylating agents, halogenated hydrocarbons, hydrazine derivatives, aldehydes, thiouram and dithiocarbamate derivatives. Arch Toxicol 46:277–285.7236006
Henderson JK, Falta RW, Freedman DL. 2009. Simulation of the effect of remediation on EDB and 1,2-DCA plumes at sites contaminated by leaded gasoline. J Contam Hydrol 108(1):29–45.19535166
Henson JM, Yates MV, Cochran JW, 1988. Microbial removal of halogenated methanes, ethanes, and ethylenes in an aerobic soil exposed to methane. FEMS Microbiol Ecol 4(3–4):193–201. 10.1111/j.1574-6968.1988.tb02664.x.
Heppel LA, Porterfield VT, Sharpless NE. 1947. Toxicology of 1,2-dichloroethane (ethylene dichloride). IV. Its detoxication by L-cystine, DL-methionine and certain other sulfur containing compounds. J Pharmacol Exp Ther 91(4):385–394.20273274
Heppel LA, Neal PA, Perrin TL, 1945. The toxicology of 1,2-dichloroethane (ethylene). III. Its acute toxicity and the effect of protective agents. J Pharmacol Exp Ther 84(1):53–63.
Heppel LA, Neal PA, Perrin TL, 1946. The toxicology of 1,2-dichloroethane (ethylene dichloride). V. The effects of daily inhalations. J Ind Hyg Toxicol 28(4):113–120.20992670
Hines RN. 2008. The ontogeny of drug metabolism enzymes and implications for adverse drug events. Pharmacol Ther 118(2):250–267. 10.1016/j.pharmthera.2008.02.005.18406467
Hirschorn SK, Dinglasan-Panlilio MJ, Edwards EA, 2007. Isotope analysis as a natural reaction probe to determine mechanisms of biodegradation of 1,2-dichloroethane. Environ Microbiol 9(7):1651–1657. 10.1111/j.1462-2920.2007.01282.x.17564600
Hogstedt C, Rohlen O, Berndtsson BS, 1979. A cohort study of mortality and cancer incidence in ethylene oxide production workers. Br J Ind Med 36(4):276–280. 10.1136/oem.36.4.276.508639
Holliger C, Schraa G, Stams AJ, 1990. Reductive dechlorination of 1,2-dichloroethane and chloroethane by cell suspensions of methanogenic bacteria. Biodegradation 1(4):253–261. 10.1007/bf00119762.1368471
Hotchkiss JA, Andrus AK, Johnson KA, 2010. Acute toxicologic and neurotoxic effects of inhaled 1,2-dichloroethane in adult Fischer 344 rats. Food Chem Toxicol 48(2):470–481. 10.1016/j.fct.2009.10.039.19887099
Hsu CY, Chiang HC, Shie RH, 2018. Ambient VOCs in residential areas near a large-scale petrochemical complex: Spatiotemporal variation, source apportionment and health risk. Environ Pollut 240:95–104. 10.1016/j.envpol.2018.04.076.29730422
Hu R, Liu G, Zhang H, 2018. Levels, characteristics and health risk assessment of VOCs in different functional zones of Hefei. Ecotoxicol Environ Saf 160:301–307. 10.1016/j.ecoenv.2018.05.056.29857234
Huang M, Zhong Y, Lin L, 2020. 1,2-Dichloroethane induces cerebellum granular cell apoptosis via mitochondrial pathway in vitro and in vivo. Toxicol Lett 322:87–97. 10.1016/j.toxlet.2020.01.004.31935479
Hubbs RS, Prusmack JJ. 1955. Ethylene dichloride poisoning. J Am Med Assoc 159(7):673–675.13263110
Hueper WC, Smith C. 1935. Fatal et178mbryogenechlorid [sic] poisoning. Am J Med Sci 189:778–784.
Humphreys WG, Kim DH, Cmarik JL, 1990. Comparison of the DNA-alkylating properties and mutagenic responses of a series of S-(2-haloethyl)-substituted cysteine and glutathione derivatives. Biochemistry 29(45):10342–10350. 10.1021/bi00497a008.2261477
IARC. 1999. 1,2-Dichloroethane. IARC Monographs on the evaluation of carcinogenic risks to humans. Volume 71. Re-evaluation of some organic chemicals, hydrazine and hydrogen peroxide. Lyon, France: International Agency for Research on Cancer. 501–529. https://monographs.iarc.who.int/wp-content/uploads/2018/06/mono71.pdf. November 28, 2022.
IARC. 2016. Agents classified by the IARC monographs, Volumes 1–123. International Agency for Research on Cancer.
Igwe OJ, Que Hee SS, Wagner WD. 1986a. Interaction between 1,2-dichloroethane and disulfiram. I. Toxicologic effects. Fundam Appl Toxicol 6(4):733–746.3710039
Igwe OJ, Que Hee SS, Wagner WD. 1986b. Interaction between 1,2-dichloroethane and tetraethylthiuram disulfide (disulfiram). II. Hepatotoxic manifestations with possible mechanism of action. Toxicol Appl Pharmacol 86(2):286–297.3787626
Igwe OJ, Que Hee SS, Wagner WD. 1988. Urinary thioether biological monitoring in the interaction between 1,2-dichloroethane and disulfiram in Sprague-Dawley rats. Am Ind Hyg Assoc J 49(1):10–16. 10.1080/15298668891379297.3344670
Inskeep PB, Koga N, Cmarik JL, 1986. Covalent binding of 1,2-dihaloalkanes to DNA and stability of the major DNA adduct, S-[2-(N7-guanyl)ethyl]glutathione. Cancer Res 46(6):2839–2844.2870801
Iowa DWAW. 1985. Synthetic organic compound sampling survey of public water supplies. Iowa Department of Water, Air and Waste Management.
IRIS. 1987. 1,2-Dichloroethane; CASRN 107–06-2. Integrated Risk Information System: Chemical assessment summary. Washington, DC: U.S. Environmental Protection Agency. https://iris.epa.gov/static/pdfs/0149_summary.pdf. November 23, 2022.
Isacson P, Bean JA, Splinter R, 1985. Drinking water and cancer incidence in Iowa. III. Association of cancer with indices of contamination. Am J Epidemiol 121(6):856–869. 10.1093/oxfordjournals.aje.a114056.4014178
Jafvert CT, Wolfe LN. 1987. Degradation of selected halogenated ethanes in anoxic sediment-water systems. Environ Toxicol Chem 6(11):827–837. 10.1002/etc.5620061102.
Jakobson I, Wahlberg JE, Holmberg B, 1982. Uptake via the blood and elimination of 10 organic solvents following epicutaneous exposure of anesthetized guinea pigs. Toxicol Appl Pharmacol 63(2):181–187. 10.1016/0041-008x(82)90039-4.7089968
Janssen DB, Scheper A, Witholt B. 1984. Biodegradation of 2-chloroethanol and 1,2-dichloroethane by pure bacterial culture. In: Houwink EH, van der Meer RR, eds. Innovations in biotechnology. Amsterdam, The Netherlands: Elsevier Science Publishers, 169–178.
Jean PA, Reed DJ. 1989. In vitro dipeptide, nucleoside, and glutathione alkylation by S-(2-chloroethyl)glutathione and S-(2-chloroethyl)-L-cysteine. Chem Res Toxicol 2(6):455–460.2519737
Jean PA, Reed DJ. 1992. Utilization of glutathione during 1,2-dihaloethane metabolism in rat hepatocytes. Chem Res Toxicol 5(3):386–391. 10.1021/tx00027a011.1504262
Jeffers PM, Ward LM, Woytowitch LM, 1989. Homogeneous hydrolysis rate constants for selected chlorinated methanes, ethanes, ethenes, and propanes. Environ Sci Technol 23(8):965–969. 10.1021/es00066a006.
Jeng CY, Chen DH, Yaw CL. 1992. Data compilation for soil sorption coefficient. Pollut Eng 24:54–60.
Jenssen D, Ramel C. 1980. The micronucleus test as part of a short-term mutagenicity test program for the prediction of carcinogenicity evaluated by 143 agents tested. Mutat Res 75:191–202.7366601
Jin X, Liao Y, Tan X, 2018a. Involvement of CYP2E1 in the course of brain edema induced by subacute poisoning with 1,2-dichloroethane in mice. Front Pharmacol 9:article 1317. 10.3389/fphar.2018.01317.30524279
Jin X, Liao Y, Tan X, 2018b. Involvement of the p38 MAPK signaling pathway in overexpression of matrix metalloproteinase-9 during the course of brain edema in 1,2-dichloroethane-intoxicated mice. Neurotoxicology 69:296–306. 10.1016/j.neuro.2018.07.022.30081051
Jin X, Wang T, Liao Y, 2019. Neuroinflammatory reactions in the brain of 1,2-DCE-intoxicated mice during brain edema. Cells 8(9):987. 10.3390/cells8090987.31461951
Johansson I, Ekstrom G, Scholte B, 1988. Ethanol-fasting- and acetone-inducible cytochromes P450 in rat liver: Regulation and characteristics of enzymes belonging to the IIB and IIE gene subfamilies. Biochemistry 27:1925–1934.3378038
Johnson MK. 1967. Metabolism of chloroethanol in the rat. Biochem Pharmacol 16(1):185–199. 10.1016/0006-2952(67)90199-2.
Jury WA, Russo D, Streile G, 1990. Evaluation of volatilization by organic chemicals residing below the soil surface. Water Resour Res 26(1):13–20. 10.1029/WR026i001p00013.
Jüttner F. 1986. Analysis of organic compounds (VOC) in the forest air of the Southern Black Forest. Chemosphere 15(8):985–992. 10.1016/0045-6535(86)90551-5.
Kaikiti C, Stylianou M, Agapiou A. 2022. TD-GC/MS analysis of indoor air pollutants (VOCs, PM) in hair salons. Chemosphere 294:133691. 10.1016/j.chemosphere.2022.133691.35065178
Kanada T, Uyeta M. 1978. Mutagenicity screening of organic solvents in microbial systems [abstract]. Mutat Res 54:215.
Kanada M, Miyagawa M, Sato M, 1994. Neurochemical profile of effects of 28 neurotoxic chemicals on the central nervous system in rats. (1) Effects of oral administration on brain contents of biogenic amines and metabolites. Ind Health 32(3):145–164. 10.2486/indhealth.32.145.7698903
Kavlock R, Chernoff N, Carver B, 1979. Teratology studies in mice exposed to municipal drinking-water concentrates during organogenesis. Food Cosmet Toxicol 17(4):343–347. 10.1016/0015-6264(79)90327-4.520968
Kellam RG, Dusetzina MG. 1980. Human exposure to ethylene dichloride: Potential for regulation ’ia EPA's proposed airborne carcinogen policy. In: Ames BN, Infante P, Reitz R, eds. Ethylene dichloride: A potential health risk? Banbury report No. 5. Cold Spring Harbor, NY: Cold Spring Harbor Laboratory, 265–274.
Kelley M, Magar VS, Hoeppel R, 1998. Intrinsic remediation of chlorinated hydrocarbons in co-contaminated groundwater plumes at the Naval Air Station Fallon, Nevada. In: Wickramanayake GB, Hinchee RE, eds. Natural attenuation: Chlorinated and recalcitrant compounds. Columbus, OH: Battelle Press, 315–320.
Kelly TJ, Mukund R, Spicer CW, 1994. Concentrations and transformations of hazardous air pollutants. Environ Sci Technol 28(8):378A–387A. 10.1021/es00057a003.
Kessels H, Hoogerwerf W, Lips J. 1992. The determination of volatile organic compounds from EPA Method 524.2 using purge-and-trap capillary gas chromatography, ECD, and FID. J Chromatogr Sci 30(7):247–255. 10.1093/chromsci/30.7.247.
Kim DH, Guengerich FP. 1989. Excretion of the mercapturic acid S-[2-N7-guanyl) ethyl]-N-acetyl cysteine in urine following administration of ethylene dibromide to rats. Cancer Res 49:5843–5847.2790795
Kim DH, Guengerich FP. 1990. Formation of the DNA adduct S-[2-(N7-guanyl)ethyl]glutathione from ethylene dibromide: effects of modulation of glutathione and glutathione S-transferase levels and lack of a role for sulfation. Carcinogenesis 11(3):419–424. 10.1093/carcin/11.3.419.2311185
King MT, Beikirch H, Eckhardt K, 1979. Mutagenicity studies with X-ray-contrast media, analgesics, antipyretics, antirheumatics and some other pharmaceutical drugs in bacterial, Drosophila and mammalian test systems. Mutat Res Genet Toxicol 66(1):33–43. 10.1016/0165-1218(79)90005-3.
Kitchin KT, Brown JL. 1994. Dose-response relationship for rat liver DNA damage caused by 49 rodent carcinogens. Toxicology 88(1–3):31–49. 10.1016/0300-483x(94)90109-0.8160204
Klaunig JE, Ruch RJ, Pereira MA. 1986. Carcinogenicity of chlorinated methane and ethane compounds administered in drinking water to mice. Environ Health Perspect 69:89–95. 10.1289/ehp.866989.3816740
Kramer RA, Foureman G, Greene KE, 1987. Nephrotoxicity of S-(2-chloroethyl)glutathione in the Fischer rat: evidence for γ-glutamyltranspeptidase-independent uptake by the kidney. J Pharmacol Exp Ther 242(2):741–748.2886652
Kramers PG, Mout HC, Bissumbhar B, 1991. Inhalation exposure in Drosophila mutagenesis assays: experiments with aliphatic halogenated hydrocarbons, with emphasis on the genetic activity profile of 1,2-dichloroethane. Mutat Res 252(1):17–33.1996129
Krill RM, Sonzogni WC. 1986. Chemical monitoring of Wi’consin's groundwater. J AWWA 78(9):70–75. 10.1002/j.1551-8833.1986.tb05812.x.
Krishnan K, Andersen ME, Clewell H, 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang R, ed. Toxicology of chemical mixtures. New York, NY: Academic Press, 399–437.
Kronevi T, Wahlberg JE, Holmberg B. 1981. Skin pathology following epicutaneous exposure to seven organic solvents. Int J Tissue React 3(1):21–30.7026421
Kurtz JP, Wolfe EM, Woodland AK, 2010. Evidence for increasing indoor sources of 1,2‐ dichloroethane since 2004 at two Colorado residential vapor intrusion sites. Ground Water Monit Remediat 30(3):107–112.
Kwok E, Atkinson R. 1995. Estimation of hydroxyl radical reaction rate constants for gas-phase organic compounds using a structure-reactivity relationship: An update. Atmos Environ 29(14):1685–1695. 10.1016/1352-2310(95)00069-b.
Lam RH F, Brown JP, Fan AM. 1994. Chemicals in California drinking water: Source of contamination, risk assessment, and drinking water standards. In: Wang R, ed. Water contamination and health: Integration of exposure assessment, toxicology, and risk assessment. New York, NY: Marcel Dekker, Inc., 15–44.
Lane RW, Riddle BL, Borzelleca JF. 1982. Effects of 1,2-dichloroethane and 1,1,1-trichloroethane in drinking water on reproduction and development in mice. Toxicol Appl Pharmacol 63(3):409–421. 10.1016/0041-008x(82)90270-8.7201685
Lanzarone NA, McCarty PL. 1990. Column studies on methanotrophic degradation of trichloroethene and 1,2-dichloroethane. Groundwater 28(6):910–919. 10.1111/j.1745-6584.1990.tb01727.x.
LaRegina J, Bozzelli JW, Harkov R, 1986. Volatile organic compounds at hazardous waste sites and a sanitary landfill in New Jersey. Environ Prog 5(1):18–27. 10.1002/ep.670050109.
Larranaga MD, Lewis RJ, Lewis RA. 2016. 1,2-Dichloroethane. In: ’Hawley's Condensed chemical dictionary. 16th ed. Hoboken, NJ: John Wiley & Sons, 584.
Lee MD, Mazierski PF, Buchanan RJ, 1995. Intrinsic in situ anaerobic biodegradation of chlorinated solvents at an industrial landfill. In: Hinchee RE, Wilson JT, Downey DC, eds. Intrinsic bioremediation. Columbus, OH: Battelle Press, 205–222.
Leeder JS, Kearns GL. 1997. Pharmacogenetics in pediatrics. Implications for practice. Pediatr Clin North Am 44(1):55–77.9057784
Lehtinen J, Veijanen A. 2011. Determination of odorous VOCs and the risk of occupational exposure to airborne compounds at the waste water treatment plants. Water Sci Technol 63(10):2183–2192.21977636
Lesage S, Jackson RE, Priddle MW, 1990. Occurrence and fate of organic solvent residues in anoxic groundwater at the Gloucester landfill, Canada. Environ Sci Technol 24(4):559–566. 10.1021/es00074a016.
Liang B, Zhong Y, Wang B, 2021. 1,2-Dichloroethane induces apoptosis in the cerebral cortexes of NIH Swiss mice through microRNA-182–5p targeting phospholipase D1 via a mitochondria-dependent pathway. Toxicol Appl Pharmacol 430:115728. 10.1016/j.taap.2021.115728.34560092
Liu JR, Fang S, Ding MP, 2010. Toxic encephalopathy caused by occupational exposure to 1, 2-Dichloroethane. J Neurol Sci 292(1–2):111–113. 10.1016/j.jns.2010.01.022.20163807
Liu G, Niu J, Zhang C, 2016. Characterization and assessment of contaminated soil and groundwater at an organic chemical plant site in Chongqing, Southwest China. Environ Geochem Health 38(2):607–618. 10.1007/s10653-015-9746-4.26193833
Livesey JC, Anders MW. 1979. In vitro metabolism of 1,2-dihaloethanes to ethylene. Drug Metab Dispos 7(4):199–203.39719
Lochhead HB, Close HP. 1951. Ethylene dichloride plastic cement: a case of fatal poisoning. J Am Med Assoc 146(14):1323–1324.14850288
Lock EA. 1989. Mechanism of nephrotoxic action due to organohalogenated compounds. Toxicol Lett 46(1–3):93–106. 10.1016/0378-4274(89)90120-3.2650039
Loffler FE, Champine JE, Ritalahti KM, 1997. Complete reductive dechlorination of 1,2-dichloropropane by anaerobic bacteria. Appl Environ Microbiol 63(7):2870–2875.16535654
Lone MI, Nazam N, Hussain A, 2016. Genotoxicity and immunotoxic effects of 1,2-dichloroethane in Wistar rats. J Environ Sci Health C Environ Carcinog Ecotoxicol Rev 34(3):169–186. 10.1080/10590501.2016.1193924.27229631
Lorah MM, Olsen LD. 1999. Degradation of 1,1,2,2-tetrachloroethane in a freshwater tidal wetland: Field and laboratory evidence. Environ Sci Technol 33(2):227–234. 10.1021/es980503t.
Luster MI, Munson AE, Thomas PT, 1988. Development of a testing battery to assess chemical-induced immunotoxicity: National Toxicology ’rogram's guidelines for immunotoxicity evaluation in mice. Fundam Appl Toxicol 10(1):2–19. 10.1016/0272-0590(88)90247-3.3280374
Ma J, Li H, Spiese R, 2016. Vapor intrusion risk of lead scavengers 1,2-dibromoethane (EDB) and 1,2-dichloroethane (DCA). Environ Pollut 213:825–832. 10.1016/j.envpol.2016.03.032.27038569
Maltoni C, Valgimigli L, Scarnato C. 1980. Long-term carcinogenic bioassays on ethylene dichloride administered by inhalation to rats and mice. In: Ethylene dichloride: A potential health risk? Cold Spring Harbor, NY: Cold Spring Harbor Laboratory, 3–33.
Martin G, Knorpp K, Huth K, 1969. Clinical features, pathogenesis and management of dichloroethane poisoning. Ger Med Mon 14(2):62–67.5781985
McCann J, Simmon V, Streitwieser D, 1975. Mutagenicity of chloroacetaldehyde, a possible metabolic product of 1,2-dichloroethane (ethylene dichloride), chloroethanol (ethylene chlorohydrin), vinyl chloride, and cyclophosphamide. Proc Natl Acad Sci U S A 72(8):3190–3193. 10.1073/pnas.72.8.3190.1059105
McCollister DD, Hollingsworth RL, Oyen F, 1956. Comparative inhalation toxicity of fumigant mixtures: Individual and joint effect of ethylene dichloride, carbon tetrachloride, and ethylene dibromide. Arch Ind Health 13:1–7.
McDonald TJ, Kennicutt MC, Brooks JM. 1988. Volatile organic compounds at a coastal Gulf of Mexico site. Chemosphere 17(1):123–136. 10.1016/0045-6535(88)90050-1.
McNally WD, Fostvedt G. 1941. Ethylene dichloride poisoning. Ind Med 10(9):373–374.
Milman HA, Story DL, Riccio ES, 1988. Rat liver foci and in-vitro assays to detect initiating and promoting effects of chlorinated ethanes and ethylenes. Ann N Y Acad Sci 534:521–530. 10.1111/j.1749-6632.1988.tb30143.x.3389679
Mitoma C, Steeger T, Jackson SE, 1985. Metabolic disposition study of chlorinated hydrocarbons in rats and mice. Drug Chem Toxicol 8(3):183–194. 10.3109/01480548508999169.4054011
Miyahara M, Toyoda M, Saito Y. 1995. Volatile halogenated hydrocarbons in foods. J Agric Food Chem 43(2):320–326. 10.1021/jf00050a011.
Miyamoto K, Urano K. 1996. Reaction rates and intermediates of chlorinated organic compounds in water and soil. Chemosphere 32(12):2399–2408. 10.1016/0045-6535(96)00142-7.
Monster AC. 1986. Biological monitoring of chlorinated hydrocarbon solvents. J Occup Med 28(8):583–588. 10.1097/00043764-198608000-00012.3746478
Morgan DL, Bucher JR, Elwell MR, 1990. Comparative toxicity of ethylene dichloride in F344/N, Sprague-Dawley and Osborne-Mendel rats. Food Chem Toxicol 28(12):839–845. 10.1016/0278-6915(90)90057-t.2276705
Morgan DL, Cooper SW, Carlock DL, 1991. Dermal absorption of neat and aqueous volatile organic chemicals in the Fischer 344 rat. Environ Res 55(1):51–63. 10.1016/s0013-9351(05)80140-9.1855490
Moriya M, Ohta T, Watanabe K, 1983. Further mutagenicity studies on pesticides in bacterial reversion assay systems. Mutat Res 116(3–4):185–216.6339892
Munson AE, Sanders VM, Douglas KA, 1982. In vivo assessment of immunotoxicity. Environ Health Perspect 43:41–52. 10.1289/ehp.824341.7060547
Nachtomi E, Alumot E, Bondi A. 1966. The metabolism of ethylene dibromide in the rat: I. Identification of detoxification of products in urine. Isr J Chem 4:239–246.
Nagano K, Umeda Y, Senoh H, 2006. Carcinogenicity and chronic toxicity in rats and mice exposed by inhalation to 1,2-dichloroethane for two years. J Occup Health 48(6):424–436. 10.1539/joh.48.424.17179635
Nakajima T, Sato A. 1979. Enhanced activity of liver drug-metabolizing enzymes for aromatic and chlorinated hydrocarbons following food deprivation. Toxicol Appl Pharmacol 50(3):549–556.516066
NAS/NRC. 1989. Report of the oversight committee. In: Biological markers in reproductive toxicology. Washington, DC: National Academies of Science, National Research Council, 15–35.
NCI. 1978. Bioassay of 1,2-dichloroethane for possible carcinogenicity. Natl Cancer Inst Carcinog Tech Rep Ser 55:1–103.12830242
NCI. 2021. NCI term browser: Ethylene dichloride (code C44383). National Cancer Institute. https://ncit.nci.nih.gov/ncitbrowser/ConceptReport.jsp?dictionary=NCI_Thesaurus&ns=NCI_Thesaurus&code=C44383. April 30, 2021.
Nestmann ER, Lee EG, Matula TI, 1980. Mutagenicity of constituents identified in pulp and paper mill effluents using the Salmonella/mammalian-microsome assay. Mutat Res 79(3):203–212.7012602
NIOSH. 1976. National occupational hazard survey (1972–74). Cincinnati, OH: National Institute for Occupational Safety and Health. PB82229881.
NIOSH. 1978. Revised recommended standard: Occupational exposure to ethylene dichloride (1,2-dichloroethane). Cincinnati, OH: National Institute for Occupational Safety and Health. PB80176092. NIOSH-78–211.
NIOSH. 1994. Method 1003: Hydrocarbons, halogenated. NIOSH manual of analytical methods, 4th edition. Cincinnati, OH: National Institute for Occupational Safety and Health. PB95154191.
NIOSH. 2019. Ethylene dichloride. NIOSH pocket guide to chemical hazards. Cincinnati, OH: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgd0271.html. November 28, 2022.
Niu Q, Zhang Q, Li L, 2009. 1,2-Dichloroethane induced toxic encephalopathy. Neurosci Res 65:S249.
NLM. 2021. PubChem compound summary: 1,2-Dichloroethane. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/11. April 30, 2021.
Nouchi T, Miura H, Kanayama M, 1984. Fatal intoxication by 1,2-dichloroethane-a case report. Int Arch Occup Environ Health 54(2):111–113. 10.1007/bf00378513.6480119
NTP. 1991. NTP technical report on the toxicity studies of 1,2-dichloroethane (ethylene dichloride) in F344/N rats, Sprague Dawley rats, Osborne-Mendel rats, and B6C3F1 mice (drinking water and gavage studies) (CAS No. 107–06-2). Research Triangle Park, NC: National Toxicology Program. NTP Tox 4. NIH Publication No. 91–3123.
NTP. 2021. 1,2-Dichloroethane, CAS No. 107–06-2. Report on carcinogens, fifteenth edition. National Toxicology Program. https://ntp.niehs.nih.gov/ntp/roc/content/profiles/dichloroethane.pdf. November 28, 2022.
Nylander P, Olofsson H, Rasmuson B, 1978. Mutagenic effects of petrol in Drosophila melanogaster: I. Effects of benzene and 1,2-dichloroethane. Mutat Res 57:163–167.96337
OECD. 2002. SIDS initial assessment report for 14th SIAM: 1,2-dichloroethane. Organisation for Economic Co-operation and Development.
Oldenhuis R, Vink RL, Janssen DB, 1989. Degradation of chlorinated aliphatic hydrocarbons by Methylosinus trichosporium OB3b expressing soluble methane monooxygenase. Appl Environ Microbiol 55(11):2819–2826. 10.1128/aem.55.11.2819-2826.1989.2624462
Oliver BG, Pugsley CW. 1986. Chlorinated contaminants in St. Clair River sediments. Water Pollut Res J Can 21(3):368–379. 10.2166/wqrj.1986.032.
OSHA. 2021a. Occupational safety and health standards. Sub–art Z - Toxic and hazardous substances. Air contaminants. Table Z-2. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. https://www.govinfo.gov/content/pkg/CFR-2021-title29-vol6/pdf/CFR-2021-title29-vol6-sec1910-1000.pdf. August 28, 2022.
OSHA. 2021b. Occupational safety and health standards for shipyard employment. Sub–art Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. https://www.govinfo.gov/content/pkg/CFR-2021-title29-vol7/pdf/CFR-2021-title29-vol7-sec1915-1000.pdf. August 28, 2022.
OSHA. 2021c. Safety and health regulations for construction. Sub–art D - Occupational health and environment controls. Gases, vapors, fumes, dusts, and mists. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55. https://www.govinfo.gov/content/pkg/CFR-2021-title29-vol8/pdf/CFR-2021-title29-vol8-sec1926-55.pdf. August 28, 2022.
Ott MG, Teta J, Greenberg HL. 1989. Lymphatic and hematopoietic tissue cancer in a chemical manufacturing environment. Am J Ind Med 16:631–644.2556914
Pang Y, Qi G, Jiang S, 2018. 1,2-Dichloroethane-induced hepatotoxicity and apoptosis by inhibition ½ERK 1/2 pathways. Can J Physiol Pharmacol 96(11):1119–1126. 10.1139/cjpp-2017-0677.29852074
Parkinson A. 1996. Biotransformation of xenobiotics. In: Klaassen C, Amdur M, Doull J, eds. Casarett an’ Doull's toxicology: The basic science of poisons. New York, NY: McGraw-Hill Companies, Inc., 133–224.
Payan JP, Beydon D, Fabry JP, 1993. Urinary thiodiglycolic acid and thioether excretion in male rats dosed with 1,2-dichloroethane. J Appl Toxicol 13(6):417–422.8288845
Payan JP, Saillenfait AM, Bonnet P, 1995. Assessment of the developmental toxicity and placental transfer of 1,2-dichloroethane in rats. Fundam Appl Toxicol 28(2):187–198. 10.1006/faat.1995.1159.8835228
Pearson CR, McConnell G. 1975. Chlorinated C1 and C2 hydrocarbons in the marine environment. Proc R Soc Lond B Biol Sci 189(1096):305–332. 10.1098/rspb.1975.0059.238199
Peijnenburg W, Eriksson L, de Groot A, 1998. The kinetics of reductive dehalogenation of a set of halogenated aliphatic hydrocarbons in anaerobic sediment slurries. Environ Sci Pollut Res Int 5(1):12–16. 10.1007/bf02986368.19002622
Pellizzari ED, Hartwell TD, Perritt RL, 1986. Comparison of indoor and outdoor residential levels of volatile organic chemicals in five U.S. geographical areas. Environ Int 12(6):619–623. 10.1016/0160-4120(86)90104-2.
Perocco P, Prodi G. 1981. DNA damage by haloalkanes in human lymphocytes cultured in vitro. Cancer Lett 13(3):213–218.6457684
Plumb RH. 1987. A comparison of ground water monitoring data from CERCLA and RCRA sites. Ground Water Monit Remediat 7(4):94–100. 10.1111/j.1745-6592.1987.tb00968.x.
Pohl HR, Scinicariello F. 2011. The impact of CYP2E1 genetic variability on risk assessment of VOC mixtures. Regul Toxicol Pharmacol 59(3):364–374.21295098
Pott WA, Benjamin SA, Yang RS. 1998. Antagonistic interactions of an arsenic-containing mixture in a multiple organ carcinogenicity bioassay. Cancer Lett 133:185–190.10072168
Prodi G, Arfellini G, Colacci A, 1986. Interaction of halocompounds with nucleic acids. Toxicol Pathol 14:438–444.3544166
Przezdziak J, Bakula S. 1975. [Acute poisoning with 1,2-dichloroethane]. Wiad Lek 28(11):983–987. (Polish)1136465
Raisbeck MF, Brown EM, Kanchanapangka S, 1990. Ketonic potentiation of haloalkane-induced nephrotoxicity. In: Goldstein RS, Hewitt WR, Hook JB, eds. Toxic interactions. San Diego, CA: Academic Press, Inc., 321–366.
Rannug U, Beije B. 1979. The mutagenic effect of 1,2-dichloroethane on Salmonella typhimurium: II. Activation by the isolated perfused rat liver. Chem Biol Interaction 24:265–285.
Rannug U, Sundvall A, Ramel C. 1978. The mutagenic effect of 1, 2-dichloroethane on Salmonella typhimurium. I. Activation through conjugatio184mbryogenestathion in vitro. Chem Biol Interact 20(1):1–16.24503
Rao KS, Murray JS, Deacon MM, 1980. Teratogenicity and reproduction studies in animals inhaling ethylene dichloride. In: Ames B, Infante P, Reitz R, eds. Ethylene dichloride: A potential health risk? Cold Spring Harbor, NY Cold Spring Harbor Laboratory 149–166.
Reeve GR, Bond GG, Lloyd JW, 1983. An investigation of brain tumors among chemical plant employees using a sample-based cohort method. J Occup Med 25:387–393.6854428
Regno V, Arulgnanendran J, Nirmalakhandan N. 1998. Microbial toxicity in soil medium. Ecotoxicol Environ Saf 39(1):48–56. 10.1006/eesa.1997.1609.9515075
Reitz RH, Fox TR, Domoradzki JY, 1980. Pharmacokinetics and macromolecular interactions of ethylene dichloride: Comparison of oral and inhalation exposures. In: Ames BN, Infante P, Reitz R, eds. Ethylene dichloride: A potential health risk? Cold Spring Harbor, NY: Cold Spring Harbor Laboratory, 135–148.
Reitz RH, Fox TR, Ramsey JC, 1982. Pharmacokinetics and macromolecular interactions of ethylene dichloride in rats after inhalation or gavage. Toxicol Appl Pharmacol 62(2):190–204. 10.1016/0041-008X(82)90117-X.7058523
Rembold H, Wallner P, Nitz S, 1989. Volatile components of chickpea (Cicer arietinum L.) seed. J Agric Food Chem 37(3):659–662. 10.1021/jf00087a018.
RePORTER. 2024. 1,2-Dichloroethane. Research Portfolio Online Reporting Tools. National Institutes of Health. https://reporter.nih.gov/. February 12, 2024.
Rodgman A, Perfetti T. 2013. Alphabetical index to chemical components in tobacco, tobacco smoke, and tobacco substitute smoke. In: The chemical components of tobacco smoke. 2nd ed. Boca Raton, FL: CRC Press, 1851. 10.1201/b13973.
Rodriguez-Arnaiz R. 1998. Biotransformation of several structurally related 2B compounds to reactive metabolites in the somatic w/w+ assay of Drosophila melanogaster. Environ Mol Mutagen 31:390–401.9654249
Roldan-Arjona T, Garchia-Pedraja MD, Luque-Romero FL, 1991. An association between mutagenicity of the Ara test of Salmonella typhimurium and carcinogenicity in rodents for 16 halogenated aliphatic hydrocarbons. Mutagenesis 6(3):199–205.1881351
Romert L, Magnusson J, Ramel C. 1990. The importance of glutathione and glutathione transferase for somatic mutations in Drosophila melanogaster induced by in vivo by 1,2-dichloroethane. Carcinogenesis 11:1399–1402.2117503
Roose P, Dewulf J, Brinkman UA, 2001. Measurement of volatile organic compounds in sediments of the Scheldt Estuary and the Southern North Sea. Water Res 35(6):1478–1488.11317895
Ruffalo CA, Gouvier WD, Pinkston JB, 2000. Ethylene dichloride: Neuropsychological effects of chronic exposure. Arch Clin Neuropsychol 15:653–850.
Sabljić A, Güsten H, Verhaar H, 1995. QSAR modelling of soil sorption. Improvements and systematics of log Koc v185mbrlog Kow correlations. Chemosphere 31(11):4489–4514. 10.1016/0045-6535(95)00327-5.
Saghir SA, Clark AJ, Gilles MM, 2006. 1,2-Dichloroethane (EDC): Limited pharmacokinetics and metabolism study in Fischer 344 rats. HAP Task Force. Submitted to the U.S. Environmental Protection Agency. Study ID: 041093. https://www.regulations.gov/document/EPA-HQ-OPPT-2003-0010-0082 (https://www.regulations.gov/document/EPA-HQ-OPPT-2003–0010-0082). April 30, 2021.
Salovsky P, Shopova V, Dancheva V, 2002. Early pneumotoxic effects after oral administration of 1,2-dichloroethane. J Occup Environ Med 44(5):475–480. 10.1097/00043764-200205000-00016.12024693
Sano M, Tappel AL. 1990. Halogenated hydrocarbon and hydroperoxide-induced lipid peroxidation in rat tissue slices. J Agric Food Chem 38(2):437–441. 10.1021/jf00092a022.
Sasaki YF, Saga A, Akasaka M, 1998. Detection of in vivo genotoxicity of haloalkanes and haloalkenes carcinogenic to rodents by the alkaline single cell gel electrophoresis (comet) assay in multiple mouse organs. Mutat Res 419(1–3):13–20.9804871
Sato A, Nakajima T, Koyama Y. 1981. Dose-related effects of a single dose of ethanol on the metabolism in rat liver of some aromatic and chlorinated hydrocarbons. Toxicol Appl Pharmacol 60:8–15.7281179
Schenk L, Rauma M, Fransson MN, 2018. Percutaneous absorption of thirty-eight organic solvents in vitro using pig skin. PLoS ONE 13(10):e0205458. 10.1371/journal.pone.0205458.30379962
Schlacter MM, Crawford AA, John JA, 1979. The effects of inhaled ethylene dichloride on embryonal and fetal development in rats and rabbits. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0515988. 86870002198.
Schönborn H, Prellwitz W, Baum P. 1970. [Consumption coagulation pathology of 1,2-dichloroethane poisoning]. Klin Wochenschr 48:822–824. (German)
Sherwoo’ RL, O'Shea W, Thomas PT, 1987. Effects of inhalation of ethylene dichloride on pulmonary defenses of mice and rats. Toxicol Appl Pharmacol 91(3):491–496. 10.1016/0041-008x(87)90071-8.3424378
Sigma-Aldrich. 2020. Safety data sheet: 1,2-Dichloroethane. Millipore Sigma. Version 6.4. https://www.sigmaaldrich.com/MSDS/MSDS/DisplayMSDSPage.do?country=US&language=en&productNumber=284505&brand=SIAL&PageToGoToURL=%2Fsafety-center.html. April 30, 2021.
Simula TP, Glancey MJ, Wolf CR. 1993. Human glutathione S-transferase-expressing Salmonella typhimurium tester strains to study the activation/detoxification of mutagenic compounds: Studies with halogenated compounds, aromatic amines and aflatoxin B1. Carcinogenesis 14:1371–1376.8330352
Singh HB, Salas LJ, Stiles RE. 1982. Distribution of selected gaseous organic mutagens and suspect carcinogens in ambient air. Environ Sci Technol 16(12):872–880. 10.1021/es00106a010.22236265
Singh B, Salas L, Viezee W, 1992. Measurement of volatile organic chemicals at selected sites in California. Atmos Environ 26(16):2929–2946. 10.1016/0960-1686(92)90285-S.
Sipes IG, Gandolfi AJ. 1980. In vitro comparative bioactivation of aliphatic halogenated hydrocarbons. In: Holmstedt B, Lauwerys R, Mercier M, , eds. Developments in toxicology and environmental science. Vol. 8: Mechanisms of toxicity and hazard evaluation. Proceedings of the Second Congress on Toxicology held in Brussels, Belgium, July 6–11, 1980. Amsterdam, The Netherlands: Elsevier/North Holland Biomedical Press, 501–506.
Snedecor G. 2004. Chloroethylenes. In: Kirk-Othmer encyclopedia of chemical technology. New York, NY: John Wiley & Sons, 253–278.
Speitel GE, Closmann FB. 1991. Chlorinated solvent biodegradation by methanotrophs in unsaturated soils. J Environ Eng (New York) 117(5):541–558. 10.1061/(ASCE)0733-9372(1991)117:5(541).
Spencer HC, Rowe VK, Adams EM, 1951. Vapor toxicity of ethylene dichloride determined by experiments on laboratory animals. AMA Arch Ind Hyg Occup Med 4(5):482–493.14884774
Spreafico F, Zuccato E, Marcucci M, 1980. Pharmacokinetics of ethylene dichloride in rats treated by different routes and its long-term inhalatory toxicity. In: Ames B, Infante P, Reitz R, eds. Ethylene dichloride: A potential health risk? Cold Spring Harbor, NY: Cold Spring Harbor Laboratory, 107–133.
Squillace PJ, Moran MJ, Price CV. 2004. VOCs in shallow groundwater in new residential/commercial areas of the United States. Environ Sci Technol 38(20):5327–5338.15543733
Stangroom SJ, Collins CD, Lester JN. 1998. Sources of organic micropollutants to lowland rivers. Environ Technol 19(7):643–666. 10.1080/09593331908616722.
Steichen J, Koelliker J, Grosh D, 1988. Contamination of farmstead wells by pesticides, volatile organics, and inorganic chemicals in Kansas. Ground Water Monit Remediat 8(3):153–160. 10.1111/j.1745-6592.1988.tb01092.x.
Stoner GD. 1991. Lung tumors in strain A mice as a bioassay for carcinogenicity of environmental chemicals. Exp Lung Res 17(2):405–423. 10.3109/01902149109064428.2050040
Storer RD, Conolly RB. 1983. Comparative in vivo genotoxicity and acute hepatotoxicity of three 1,2-dihaloethanes. Carcinogenesis 4(11):1491–1494. 10.1093/carcin/4.11.1491.6357525
Storer RD, Conolly RB. 1985. An investigation of the role of microsomal oxidative metabolism in the in vivo genotoxicity of 1,2-dichloroethane. Toxicol Appl Pharmacol 77:36–46.3966241
Storer RD, Jackson NM, Conolly RB. 1984. In vivo genotoxicity and acute hepatotoxicity of 1,2-dichloroethane in mice: Comparison of oral, intraperitoneal, and inhalation routes of exposure. Cancer Res 44:4267–4271.6467188
Stucki G, Thuer M. 1994. Increased removal capacity for 1,2-dichloroethane by biological modification of the granular activated carbon process. Appl Microbiol Biotechnol 42(1):167–172.7765815
Stucki G, Krebser U, Leisinger T. 1983. Bacterial growth on 1,2-dichloroethane. Experientia 39(11):1271–1273. 10.1007/BF01990365.6641901
Suffet IH, Brenner L, Cairo PR. 1980. GC/MS identification of trace organics in Philadelphia drinking waters during a 2-year period. Water Res 14(7):853–867. 10.1016/0043-1354(80)90266-3.
Suguro M, Numano T, Kawabe M, 2017. Lung tumor induction by 26-week dermal application of 1,2-dichloroethane in CB6F1-Tg rasH2 mice. Toxicol Pathol 45(3):427–434. 10.1177/0192623317701003.28421967
Sun Q, Wang G, Gao L, 2016. Roles of CYP2E1 in 1,2-dichloroethane-induced liver damage in mice. Environ Toxicol 31(11):1430–1438. 10.1002/tox.22148.25926354
Sweeney LM, Gargas ML. 2016. Route-to-route extrapolation of 1,2-dichloroethane studies from the oral route to inhalation using physiologically based pharmacokinetic models. Regul Toxicol Pharmacol 81:468–479. 10.1016/j.yrtph.2016.10.005.27756559
Sweeney LM, Saghir SA, Gargas ML. 2008. Physiologically based pharmacokinetic model development and simulations for ethylene dichloride (1,2-dichloroethane) in rats. Regul Toxicol Pharmacol 51(3):311–323. 10.1016/j.yrtph.2008.05.002.18579268
Tabak HH, Quave SA, Mashni CI, 1981. Biodegradability studies with organic priority pollutant compounds. J Water Pollut Control Fed 53(10):1503–1518.
Tafazoli M, Baeten A, Geerlings P, 1998. In vitro mutagenicity and genotoxicity study of a number of short-chain chlorinated hydrocarbons using the micronucleus test and the alkaline single cell gel electrophoresis technique (Comet assay) in human lymphocytes: a structure-activity relationship (QSAR) analysis of the genotoxic and cytotoxic potential. Mutagenesis 13(2):115–126. 10.1093/mutage/13.2.115.9568582
Take M, Takanobu K, Takeuchi T, 2013. Distribution of blood and tissue concentrations in rats by inhalation exposure to 1,2-dichloroethane. J Environ Sci Health A Tox Hazard Subst Environ Eng 48(9):1031–1036. 10.1080/10934529.2014.928193.23573923
Tan EL, Hsie AW. 1981. Mutagenicity and cytotoxicity of haloethanes as studied in the CHO/HGPRT system. Mutation Research 90:183–191.7035935
Taningher M, Parodi S, Grilli S, 1991. Lack of correlation between alkaline DNA fragmentation and DNA covalent binding induced by polychloroethanes after in vivo administration. Problems related to the assessment of a carcinogenic hazard. Cancer Detect Prev 15(1):35–39.2044072
Teta MJ, Ott MG, Schnatter AR. 1989. An update of mortality due to brain neoplasms and other causes among employees of petrochemical facility. J Occup Med 33:45–51.
Theiss JC, Stoner GD, Shimkin MB, 1977. Test for carcinogenicity of organic contaminants of United States drinking waters by pulmonary tumor response in strain A mice. Cancer Res 37:2717–2720.872098
Thier R, Taylor JB, Pemble SE, 1993. Expression of mammalian glutathione S-transferase 5–5 in Salmonella typhimurium TA1535 leads to base-pair mutations upon exposure to dihalomethanes. Proc Natl Acad Sci U S A 90:8576–8580.8378332
Tilley SK, Reif DM, Fry RC. 2017. Incorporating ToxCast and Tox21 datasets to rank biological activity of chemicals at Superfund sites in North Carolina. Environ Int 101:19–26. 10.1016/j.envint.2016.10.006.28153528
Torkelson TR, Rowe VK. 1981. Halogenated aliphatic hydrocarbons. In:’ Patty's industrial hygiene and toxicology. Vol. 2B: Toxicology. New York, NY: John Wiley & Sons, 3491–3497.
TRI21. 2022. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: U.S. Environmental Protection Agency. https://www.epa.gov/enviro/tri-search. December 8, 2022.
Tsuruta H. 1975. Percutaneous absorption of organic solvents: 1. Comparative study of the in vivo percutaneous absorption of chlorinated solvents in mice. Ind Health 13:227–236.
U.S. Census. 2018. Trade definitions. U.S. Census Bureau. https://www.census.gov/foreign-trade/reference/definitions/index.html#general_imports. April 30, 2021.
Urusova TP. 1953. [The possible presence of dichloroethane in human milk with exposure in industrial conditions]. Gig Sanit 18:36–37. (Russian)
USITC. 2019. 1,2-Dichloroethane import and export data. U.S. International Trade Commission. https://dataweb.usitc.gov/. April 30, 2021.
Vamvakas S, Dekant W, Henschler D. 1989. Assessment of unscheduled DNA synthesis in a cultured line of renal epithelial cells exposed to cysteine-S-conjugates of haloalkenes and haloalkanes. Mutat Res 222:329–335.2704384
Vamvakas S, Dekant W, Schiffmann D, 1988. Induction of unscheduled DNA synthesis and micronucleus formation in Syrian hamster embryo fibroblasts treated with cysteine S-conjugates of chlorinated hydrocarbons. Cell Biol Toxicol 4:393–404.3228710
van Bladeren PJ. 1983. Metabolic activation of xenobiotics: Ethylene dibromide and structural analogs. J Am Coll Toxicol 2:73–83.
van Bladeren PJ, van der Gen A, Breimer DD, 1979. Stereoselective activation of vicinal dihalogen compounds to mutagens by glutathione conjugation. Biochem Pharmacol 28(16):2521–2524.389247
van Bladeren PJ, Breimer DD, Rotteveel-Smijs GM, 1981. The relation between the structure of vicinal dihalogen compounds and their mutagenic activation via conjugation to glutathione. Carcinogenesis 2(6):499–505. 10.1093/carcin/2.6.499.7273330
Van Duuren BL, Goldschmidt BM, Loewengart G, 1979. Carcinogenicity of halogenated olefinic and aliphatic hydrocarbons in mice. J Natl Cancer Inst 63:1433–1439.292813
van Esch GJ, Kroes R, van Logten MJ, 1977. Ninety-day toxicity study with 1,2-dichloroethane (DCE) in rats. Bilthoven, Netherlands: National Institute of Public Health and Environmental Hygiene.
Vandenbergh PA, Kunka BS. 1988. Metabolism of volatile chlorinated aliphatic hydrocarbons by Pseudomonas fluorescens. Appl Environ Microbiol 54(10):2578–2579.3144246
Ventura F, Romero J, Parés J. 1997. Determination of dicyclopentadiene and its derivatives as compounds causing odors in groundwater supplies. Environ Sci Technol 31(8):2368–2374. 10.1021/es960987y.
Verschueren K. 1996. 1,2-Dichloroethane. In: Handbook of environmental data on organic chemicals. 3rd ed. New York, NY: Van Nostrand Reinhold Company, 963–965.
Vieira I, Pasanen M, Raunio H, 1998. Expression of CYP2E1 in human lung and kidney during development and in full-term placenta: a differential methylation of the gene is involved in the regulation process. Pharmacol Toxicol 83(5):183–187.9834965
Vogel EW, Nivard MJ M. 1993. Performance of 181 chemicals in a Drosophila assay predominantly monitoring interchromosomal mitotic recombination. Mutagenesis 8(1):57–81.8450769
Vozovaya MA. 1974. [Development of the progeny of 2 generations obtained from females exposed to the effects of dichloroethane]. Gig Sanit (7):25–28. (Russian)
Vozovaya MA. 1977. [The effect of dichloroethane on the sexual cycle and embryogenesis of experimental animals]. Akusk Ginekol (Moscow) 2:57–59. (Russian)
Wallace LA. 1991. Comparison of risks from outdoor and indoor exposure to toxic chemicals. Environ Health Perspect 95:7–13. 10.1289/ehp.91957.1821381
Wallace L, Pellizzari E, Hartwell T, 1984. Personal exposure to volatile organic compounds: I. Direct measurements in breathing-zone air, drinking water, food and exhaled breath. Environ Research 35:293–319.
Wallace L, Pellizzari E, Hartwell T, 1986. Concentrations of 20 volatile organic compounds in the air and drinking water of 350 residents of New Jersey compared with concentrations in their exhaled breath. J Occup Med 28(8):603–608.3746480
Wallace LA, Pellizzari E, Leaderer B, 1987. Emissions of volatile organic compounds from building materials and consumer products. Atmos Environ 21(2):385–393. 10.1016/0004-6981(87)90017-5.
Wang G, Qi Y, Gao L, 2013. Effects of subacute exposure to 1,2-dichloroethane on mouse behavior and the related mechanisms. Hum Exp Toxicol 32(9):983–991. 10.1177/0960327112470270.23263856
Wang G, Yuan Y, Zhang J, 2014. Roles of aquaporins and matrix metalloproteinases in mouse brain edema formation induced by subacute exposure to 1,2-dichloroethane. Neurotoxicol Teratol 44:105–112. 10.1016/j.ntt.2014.06.005.24964198
Wang T, Xu D, Fan Q, 2017. 1,2-Dichloroethane impairs glucose and lipid homeostasis in the livers of NIH Swiss mice. Toxicology 380:38–49. 10.1016/j.tox.2017.02.005.28189721
Wang G, Yuan Y, Gao L, 2018. Disruption of intracellular ATP generation and tight junction protein expression during the course of brain edema induced by subacute poisoning of 1,2-dichloroethane. Front Neurosci 12:article 12. 10.3389/fnins.2018.00012.
Watanabe K, Liberman RG, Skipper PL, 2007. Analysis of DNA adducts formed in vivo in rats and mice from 1,2-dibromoethane, 1,2-dichloroethane, dibromomethane, and dichloromethane using HPLC/accelerator mass spectrometry and relevance to risk estimates. Chem Res Toxicol 20(11):1594–1600. 10.1021/tx700125p.17907789
Watwood ME, White CS, Dahm CN. 1991. Methodological modifications for accurate and efficient determination of contaminant biodegradation in unsaturated calcareous soils. Appl Environ Microbiol 57(3):717–720.16348438
Waxweiler RJ, Alexander V, Leffingwell SS, 1983. Mortality from brain tumor and other causes in a cohort of petrochemical workers. J Natl Cancer Inst 70:75–81.6571925
Weiss G. 1980. Ethylene dichloride. In: Hazardous chemicals data book. Vol. 4. Park Ridge, NJ: Noyes Data Corporation, 433.
Westrick JJ, Mello JW, Thomas RF. 1984. The groundwater supply survey. J Am Water Works Assoc 76(5):52–59.
WHO. 1995. International program on chemical safety. Geneva, Switzerland: World Health Organization. Environmental Health Criteria 176.
WHO. 2000. Air quality guidelines for Europe. World Health Organization. https://apps.who.int/iris/handle/10665/107335. November 23, 2022.
WHO. 2022. Guidelines for drinking-water quality. Fourth edition incorporating the first and second addenda. World Health Organization. https://www.who.int/publications/i/item/9789240045064. June 22, 2022.
Williams GM, Mori H, McQueen CA. 1989. Structure-activity relationships in the rat hepatocyte DNA-repair test for 300 chemicals. Mutat Res 221(3):263–286. 10.1016/0165-1110(89)90039-0.2682231
Wilson JT, Enfield CG, Dunlap WJ, 1981. Transport and fate of selected organic pollutants in a sandy soil. J Environ Qual 10(4):501–506. 10.2134/jeq1981.00472425001000040016x.
Wilson JT, McNabb JF, Balkwill DL, 1983. Enumeration and characterization of bacteria indigenous to a shallow water-table aquifer. Groundwater 21(2):134–142. 10.1111/j.1745-6584.1983.tb00710.x.
Wirtschafter ZT, Schwartz ED. 1939. Acute ethylene dichloride poisoning. J Ind Hyg Toxicol 21:126–131.
Withey JR, Collins BT. 1980. Chlorinated aliphatic hydrocarbons used in the foods industry: The comparative pharmacokinetics of methylene chloride, 1,2-dichloroethane, chloroform and trichloroethylene after i.v. administration in the rat. J Environ Pathol Toxicol 3:313–332.7441087
Withey JR, Karpinski K. 1985. The fetal distribution of some aliphatic chlorinated hydrocarbons in the rat after vapor phase exposure. Biol Res Pregnancy Perinatol 6(2):79–88.4016168
Withey JR, Collins BT, Collins PG. 1983. Effect of vehicle on the pharmacokinetics and uptake of four halogenated hydrocarbons from the gastrointestinal tract of the rat. J Appl Toxicol 3(5):249–253. 10.1002/jat.2550030506.6662999
Witt KL, Knapton A, Wehr CM, 2000. Micronucleated erythrocyte frequency in peripheral blood of B6C3F1 mice from short-term, prechronic, and chronic studies of the NTP carcinogenesis bioassay program. Environ Mol Mutagen 36(3):163–194.11044899
WQP. 2020. Water quality portal data: 1,2-Dichloroethane. National Water Quality Monitoring Council. https://www.waterqualitydata.us/portal/. August 18, 2020.
Yamamoto K, Fukushima M, Kakutani N, 1997. Volatile organic compounds in urban rivers and their estuaries in Osaka, Japan. Environ Pollut 95(1):135–143.15093482
Yang J, Wang T, Jin X, 2021. Roles of crosstalk between astrocytes and microglia in triggering neuroinflammation and brain edema formation in 1,2-dichloroethane-intoxicated mice. Cells 10(10):2647. 10.3390/cells10102647.34685627
Yao S, Wang Q, Zhang J, 2021. Ambient volatile organic compounds in a heavy industrial city: Concentration, ozone formation potential, sources, and health risk assessment. Atmos Pollut Res 12(5):101053. 10.1016/j.apr.2021.101053.
Yllner S. 1971. Metabolism of 1,2-dichloroethane-14C in the mouse. Acta Pharmacol Toxicol 30:257–265.
Yodaiken RE, Babcock JR. 1973. 1,2-Dichloroethane poisoning. Arch Environ Health 26(5):281–284. 10.1080/00039896.1973.10666277.4696388
Zeng N, Jiang H, Fan Q, 2018. Aberrant expression of miR-451a contributes to 1,2-dichloroethane-induced hepatic glycerol gluconeogenesis disorder by inhibiting glycerol kinase expression in NIH Swiss mice. J Appl Toxicol 38(2):292–303. 10.1002/jat.3526.28960355
Zeng N, Zhang Z, Jiang H, 2019. LncRNA-241 inhibits 1,2-dichloroethane-induced hepatic apoptosis. Toxicol in Vitro 61:104650.31520740
Zhan F, Zheng W, Liu L, 2011. Diagnosis and prognosis evaluation of 1,2-dichloroethane encephal–pathy - magnetic resonance imaging combined with diffusion tensor imaging and magnetic resonance spectroscopy study. Neurol India 59(1):108–110. 10.4103/0028-3886.76884.21339675
Zhang LH, Jenssen D. 1994. Studies on intrachromosomal recombination in SP5/V79 Chinese hamster cells upon exposure to different agents related to carcinogenesis. Carcinogenesis 15:2303–2310.7955071
Zhang L, Jin YP. 2019. Toxic effects of combined treatment of 1,2-dichloroethane and ethanol on mouse brain and the related mechanisms. J Biochem Mol Toxicol 33(5):e22294. 10.1002/jbt.22294.30664321
Zhang Q, Niu Q, Li L, 2011. Establishment of a poisoned animal model of toxic encephalopathy induced by 1,2-dichloroethane. Int J Immunopathol Pharmacol 24(1 Suppl):79s–83s.21329570
Zhang Y, Li G, Zhong Y, 2017. 1,2-Dichloroethane induces reproductive toxicity mediated by the CREM/CREB signaling pathway in male NIH Swiss mice. Toxicol Sci 160(2):299–314. 10.1093/toxsci/kfx182.28973639
Zhao SF, Zhang XC, Bao YS. 1984. The study on the effects of 1,2-dichloroethane on the development of mice. Chinese J Ind Hyg Occup Dis 2:343–346.
Zhao SF, Zhang XC, Bao YS. 1989. The study on the effects of 1,2-dichloroethane on reproductive function. Chinese J Prevent Med 23:199–202.
Zhong Y, Liang B, Hu M, 2020. MicroRNA-29b-3p aggravates 1,2-dichloroethane-induced brain edema by targeting aquaporin 4 in Sprague-Dawley rats and CD-1 mice. Toxicol Lett 319:160–167. 10.1016/j.toxlet.2019.11.011.31734271
Zhong Y, Liang B, Meng H, 2022. 1,2-Dichloroethane induces cortex demyelination by depressing myelin basic protein via inhibiting aquaporin 4 in mice. Ecotoxicol Environ Saf 231:113180. 10.1016/j.ecoenv.2022.113180.35026584
Zhou X, Zhou W, Zhou J, 2015. 1,2-Dichloroethane-induced toxic leukoencephalopathy with a brain biopsy. Neurol Sci 36(5):817–819. 10.1007/s10072-014-1949-4.25217108
Zhou X, Cao Y, Leuze C, 2016. Early non-invasive detection of acute 1,2-dichloroethane-induced toxic encephalopathy in rats. In Vivo 30(6):787–793. 10.21873/invivo.10995.27815462