# CONTRIBUTORS & REVIEWERS

## CHEMICAL MANAGER TEAM

- Carolyn Harper, Ph.D. (Lead)
  Hana Pohl, M.D., Ph.D.
- ATSDR, Office of Innovation and Analytics,
  Toxicology Section, Atlanta, GA
- Ryan Klein, Ph.D.
  Adriana Antezana, M.S.
  Kerry Diskin, Ph.D.
  Hannah Derrick, B.S.
  Sara Sokolinski, B.S.
  AJ Casner, B.S.
  Meghan Lynch D.Sc.
- Abt Associates, Cambridge, MA
  Claire Heit, Ph.D.
  Heather Carlson-Lynch, M.S., D.A.B.T.
  Julie Klotzbach, Ph.D.
  Julie Melia, Ph.D., D.A.B.T.
  Ramsey Hanna, Ph.D.
  Mario Citra, Ph.D.
- SRC, Inc., North Syracuse, NY

## REVIEWERS

Interagency Minimal Risk Level Workgroup:

- Includes ATSDR; National Center for Environmental Health (NCEH); National Institute for Occupational Safety and Health (NIOSH); U.S. Environmental Protection Agency (EPA); National Toxicology Program (NTP).

Additional reviews for science and/or policy:

- ATSDR, Office of Community Health Hazard Assessment; ATSDR, Office of Capacity Development and Applied Prevention Science; ATSDR, Office of Science; NCEH, Division of Laboratory Sciences; NCEH, Division of Environmental Health Science and Practice, EPA.

## PEER REVIEWERS

1. Jordan N. Smith, Ph.D.; Joint Appointment, Department of Environmental and Molecular Toxicology (EMT); Oregon State University (reviewed Draft for Public Comment Profile)
2. John C. Lipscomb, Ph.D., D.A.B.T, F.A.T.S; Lipscomb and Associates, PLLC; Sherwood, Arkansas (reviewed Draft for Public Comment Profile)
3. James V. Buckner, Ph.D.; Professor Emeritus of Pharmacology and Toxicology; Department of Pharmaceutical & Biomedical Sciences; College of Pharmacy; University of Georgia; Athens, Georgia (reviewed Draft for Public Comment Profile and MRLs in the Post-Public Comment Profile)
4. David C. Dorman, DVM, Ph.D., DABVT, DABT; Professor of Toxicology; North Carolina State University; College of Veterinary Medicine; Department of Molecular Biomedical Sciences; Raleigh, North Carolina (reviewed MRLs in the Post-Public Comment Profile)
5. Ivan Rusyn, M.D., Ph.D.; University Professor; KC Donnelly Professor of Veterinary Physiology and Pharmacology; Chair, Interdisciplinary Faculty of Toxicology; Director, Superfund Research Center; Texas A&M University; College Station, Texas (reviewed MRLs in the Post-Public Comment Profile)

These experts collectively have knowledge of toxicology, chemistry, and/or health effects. All reviewers were selected in conformity with Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

ATSDR scientists review peer reviewers’ comments and determine whether changes will be made to the profile based on comments. The peer reviewers’ comments and responses to these comments are part of the administrative record for this compound.

The listing of peer reviewers should not be understood to imply their approval of the profile's final content. The responsibility for the content of this profile lies with ATSDR.