# VERSION HISTORY

Date | Description
July 2024 | Final toxicological profile released
January 2022 | Draft for public comment toxicological profile released
September 2001 | Final toxicological profile released