# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding 1,2-dichloroethane in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for 1,2-dichloroethane.

Table 7-1 Regulations and Guidelines Applicable to 1,2-Dichloroethane

Agency | Description | Information | Reference
Air
EPA | RfC | Not evaluated | IRIS 1987
| Provisional peer-reviewed toxicity values | | EPA 2010
| Provisional chronic RfC | 0.007 mg/m^3^ (0.0017 ppm)
| Provisional subchronic RfC | 0.07 mg/m^3^ (0.017 ppm)
WHO | Air quality guidelines | 0.7 mg/m^3^ ^a^ | WHO 2000
Water & Food
EPA | Drinking water standards and health advisories | | EPA 2018c
| 1-Day health advisory (10-kg child) | 0.7 mg/L
| 10-Day health advisory (10-kg child) | 0.7 mg/L
| Lifetime health advisory | No data
| 10^−4^ Cancer risk | 0.04 mg/L
| National primary drinking water regulations | | EPA 2009
| MCL | 0.005 mg/L
| MCLG | 0 mg/L
| RfD | Not evaluated | IRIS 1987
| Provisional peer-reviewed toxicity values | | EPA 2010
| Provisional subchronic RfD | 0.02 mg/kg/day
WHO | Drinking water quality guidelines | 0.03 mg/L | WHO 2022
FDA | Allowable level in bottled water | 0.005 mg/L | FDA 2017
| Concentration limit in pharmaceutical products | 5 ppm | FDA 2018
| Substances added to food (formerly EAFUS) | Allowed under certain color, food additive and food contact substance regulations with limitations | FDA 2022
| Food additive levels | Not to exceed:
| Residues from use as solvent in extraction process of:
| Whole fish protein concentrate | 5 ppm | FDA 2021a
| Modified hop extract | 150 ppm | FDA 2021a
| Spice oleoresins | 30 ppm | FDA 2021b
| Animal byproducts for use in animal feeds | 300 ppm | FDA 2021c
| Use in flume water for washing sugar beets | 0.2 ppm | FDA 2021b
Cancer
HHS | Carcinogenicity classification | Reasonably anticipated to be a human carcinogen | NTP 2021
EPA | Carcinogenicity classification | B2^b^ | IRIS 1987
| Inhalation unit risk | 2.6×10^−5^ per μg/m^3^
| Oral slope factor | 9.1×10^−2^ per mg/kg/day
IARC | Carcinogenicity classification | Group 2B^c^ | IARC 1999
Occupational
OSHA | PEL (8-hour TWA) for general industry, shipyards, and construction | 50 ppm^d^ | OSHA 2021a, 2021b, 2021c
| Ceiling concentration for general industry | 100 ppm^e^, 200 ppm (peak) | OSHA 2021a
NIOSH | REL (up to 10-hour TWA) | 1 ppm^d^ | NIOSH 2019
| STEL | 2 ppm
| IDLH | 50 ppm
Emergency Criteria
EPA | AEGLs-air | No data | EPA 2018d
DOE | PACs-air | | DOE 2018a
| PAC-1^f^ | 50 ppm
| PAC-2^f^ | 200 ppm
| PAC-3^f^ | 300 ppm

a 24-hour TWA.

b B2: probable human carcinogen.

c Group 2B: possibly carcinogenic to humans.

d Potential occupational carcinogen.

e Not to exceed this concentration at any time during an 8-hour shift, except for up to 5 minutes in any 3 hours, up to the acceptable peak concentration.

f Definitions of PAC terminology are available from DOE (2018b).

AEGL = acute exposure guideline levels; DOE = Department of Energy; EAFUS = Everything Added to Food in the United States; EPA = U.S. Environmental Protection Agency; FDA = Food and Drug Administration; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; MCL = maximum contaminant level; MCLG = maximum contaminant level goal; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; STEL = short-term exposure limit; TWA = time-weighted average; WHO = World Health Organization