# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

1,2-Dichloroethane is a colorless, oily liquid composed of two carbon atoms bonded together, with each carbon atom also bonded to one chlorine atom, and two hydrogen atoms. 1,2-Dichloroethane is primarily used in the production of vinyl chlorides, and as a solvent in organic synthesis. 1,2-Dichloroethane was previously used as an insect and soil fumigant, in cleaning products (especially for use on textiles), and in adhesives. 1,2-Dichloroethane is produced by chlorination of ethylene using a catalyst.

Table 4-1 lists common synonyms, trade names, and other pertinent identification information for 1,2-dichloroethane.

Table 4-1 Chemical Identity of 1,2-Dichloroethane

Characteristic | Information
Chemical name | 1,2-Dichloroethane
Synonym(s) and Registered trade name(s) | 1,2-Dichloroethane; 1,2-Ethylene dichloride; alpha,beta-Dichloroethane; Borer sol; Brocide; Destruxol borer-sol; Di-chlor-mulsion; Dichlor-Mulsion; Dichloremulsion; Dichloroethylene; Dutch liquid; Dutch oil; EDC; Ethane dichloride; Ethylene dichloride; Ethylenechloride; Ethylene dichloride; Glycol dichloride; sym-Dichloroethane
Chemical formula | C_2_H_4_Cl_2_
Chemical structure | [image]
CAS Registry Number | 107-06-2

CAS = Chemical Abstracts Service

Source: NLM 2021

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

1,2-Dichloroethane is a colorless oily liquid. It is slightly soluble in water and is very soluble in a number of organic solvents. It also has a high vapor pressure and is therefore expected to volatilize in the environment. 1,2-Dichloroethane has a very low K_oc_ and is expected to be very mobile in the environment. Table 4-2 lists important physical and chemical properties of 1,2-dichloroethane.

Table 4-2 Physical and Chemical Properties of 1,2-Dichloroethane

Property | Information | Reference
Molecular weight | 98.96 | NLM 2021
Color | Clear, colorless | NLM 2021
Physical state | Oily liquid; heavy liquid | NLM 2021
Melting point(s) | −35.6°C | NLM 2021
Boiling point(s) | 83.4°C | NLM 2021
Critical temperature and pressure | 563 K and 5,360 kPa | NLM 2021
Density | 1.2454 at 25°C | NLM 2021
Taste | Sweet | NLM 2021
Taste threshold: | No data
Odor | Pleasant, chloroform-like; sweet | NLM 2021
Odor threshold:
Water | 20 mg/L | Verschueren 1996
Air | 12 ppm | Torkelson and Rowe 1981
| 50 ppm | Verschueren 1996
| 100 ppm | Weiss 1980
Solubility:
Water | 8,600 mg/L at 25°C | NLM 2021
| 8,690 mg/L at 20°C | Verschueren 1996
Organic solvent(s) | Miscible with alcohol, chloroform, ether; soluble in acetone, benzene, chloroform | NLM 2021
Inorganic solvent(s) | No data
Partition coefficients:
Log K_ow_ | 1.48 | NLM 2021
Log K_oc_ | 1.5
Vapor pressure at 25 °C | 78.9 mmHg (10.5 kPa) | NLM 2021
Henry's law constant at 25 °C | 1.18×10^−3^ atm-m^3^/mole | NLM 2021
Degradation half-life in air via reaction with OH radicals | 2.48×10^−13^ cm^3^/molecule-second at 25°C | NLM 2021
Dissociation constants: | No data
Autoignition temperature | 413°C | NLM 2021
Flash point | 13°C | NLM 2021
Flammability limits in air | 6.2–16% by volume | NLM 2021
Conversion factors: | 1 ppm in air = 4 mg/m^3^ | NLM 2021
| ppm(v/v)×4.05=mg/m^3^ | Torkelson and Rowe 1981
| mg/m^3^×0.247=ppm(v/v) | Torkelson and Rowe 1981
Explosive limits | 6.2–15.9% | NLM 2021
Incompatibilities and reactivity | Incompatible with strong oxidizing agents; violent reaction with aluminum, dinitrogen tetroxide, ammonia, dimethylaminopropylamine | NLM 2021