# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Office of Innovation and Analytics, Toxicology Section, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Office of Innovation and Analytics, Toxicology Section, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S106–5, Atlanta, Georgia 30329–4027.

## 1,2-Dichloroethane Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2-Dichloroethane
CAS Numbers: | 107-06-2
Date: | July 2024
Profile Status: | Final
Route: | Inhalation
Duration: | Acute
MRL: | 0.1 ppm (0.4 mg/m^3^)
Critical Effect: | Degeneration, with necrosis, olfactory epithelium
Reference: | Hotchkiss et al. 2010
Point of Departure: | BMCL_10_ of 57.62 ppm (BMCL_HEC_ of 3.84 ppm)
| (BMCL_HEC_ of 3.84 ppm)
Uncertainty Factor: | 30
LSE Graph Key: | 5
Species: | Rat

MRL Summary: An acute-duration inhalation MRL of 0.1 ppm was derived for 1,2-dichloroethane based on an increased incidence of nasal epithelium degeneration/necrosis in rats administered 1,2-dichloro-ethane via inhalation (Hotchkiss et al. 2010). The MRL is based on a BMCL_10_ of 57.62 ppm converted to human equivalent concentration (BMCL_HEC_) of 3.84 ppm and divided by a total uncertainty factor of 30 (3 for extrapolation from animals to humans with dosimetric adjustment and 10 for human variability).

Selection of the Critical Effect: A number of studies have evaluated the toxicity of 1,2-dichloroethane following acute-duration inhalation exposure; these studies examine a wide range of endpoints including neurotoxicity (Heppel et al. 1945; Hotchkiss et al. 2010; Jin et al. 2018a, 2018b; Niu et al. 2009; Wang et al. 2013, 2014, 2018; Zhang et al. 2011; Zhou et al. 2016), liver and kidney effects (Hotchkiss et al. 2010; Spencer et al. 1951), respiratory effects (Chan et al. 2002; Hotchkiss et al. 2010), immunotoxicity (Sherwood et al. 1987), developmental toxicity (Schlacter et al. 1979), reproductive toxicity (Zhang et al. 2017), gastrointestinal toxicity (Heppel et al. 1945), and hematotoxicity (Spencer et al. 1951). The LOAELs for these studies range from 50 to 3,000 ppm; a summary of the lowest NOAEL and LOAEL values is presented in Table A-1. To provide a consistent basis for comparison across species, the NOAELs and LOAELs were adjusted for intermittent exposure and converted to human equivalent concentrations (HECs) following EPA (1994a) methodology. For systemic (extrarespiratory) effects, the HEC is calculated by multiplying the duration-adjusted animal NOAEL or LOAEL by the ratio of the blood:gas partition coefficients in animals and humans. Gargas et al. (1989) estimated a blood:air partition coefficient of 19.5±0.7 for 1,2-dichloroethane in humans; however, a blood:air partition coefficient for mice was not located. The default value of 1 was used for the ratio in calculating the HEC values for reduced locomotor activity in mice (Wang et al. 2013). For effects on the respiratory tract, the regional gas dose ratio (RGDR) corresponding to the part of the respiratory tract that is affected was used. Thus, the RGDR for extrathoracic effects was used for nasal lesions and the RGDR_ET_ (extrathoracic) value for rats (0.20) was calculated as follows:

R G D R_E T_ = (V_E_a__)/(S A_a_) ÷ (V_E_h__)/(S A_h_)

where: V_E_a__ = ventilation rate for male and female F344 rats = 0.211 L/minute (EPA 1994a) S A_a_ = surface area of the extrathoracic region in rats = 15 cm^2^ (EPA 1994a)

Table A-1 Summary of Relevant NOAEL and LOAEL Values Following Acute-Duration Inhalation Exposure to 1,2-Dichloroethane

Species | Duration | NOAEL (ppm) | LOAEL or SLOAEL (ppm) | NOAEL_ADJ_ (ppm)^a^ | LOAEL_ADJ_ (ppm)^a^ | NOAEL_HEC_ (ppm) | LOAEL_HEC_ (ppm) | Effect | Reference
Respiratory effects
Rat/Fischer 344 | 8 hours | 50 | 100 | 17 | 33 | 3.3 | 6.6 | Olfactory epithelium degeneration/necrosis | Hotchkiss et al. 2010
Neurological effects
Mouse/Albino | 3.5 hours/day; 10 days | 56 | 111 | 8.2 | 16.2 | 8.2 | 16.2 | Reduced locomotor activity | Wang et al. 2013
Reproductive effects
Mouse (Swiss-Webster) | 6 hours/day, 7 days | 25 | 86 (SLOAEL) | 6.25 | NA | 6.25 | NA | Increased abnormal sperm^b^ | Zhang et al. 2017

a NOAEL and LOAEL values were adjusted from intermittent daily exposures to the equivalent of 24-hour continuous exposure. The duration adjusted values were calculated as:

A d j u s t e d d a i l y d o s e = I n t e r m i t t e n t d o s e × (hours per day exposed)/(24 hours) × (days per week exposed)/(7 days)

b Histopathological effects at 86 ppm (vacuolar degeneration of germ cells in the seminiferous tubules and sloughing of spermatogenic cells into the lumen of the testes) are considered to be serious adverse effects.

LOAEL = lowest-observed-adverse-effect level; MRL = Minimal Risk Level; NA = not applicable (MRLs cannot be based on exposure levels that produce serious adverse effects); NOAEL = no-observed-adverse-effect level; NOAEL_ADJ_ = NOAEL adjusted to continuous exposure; NOAEL_HEC_ = NOAEL_ADJ_ converted to human equivalent concentration (HEC; see text); SLOAEL = serious lowest-observed-adverse-effect level

V_E_h__ = ventilation rate for humans = 13.8 L/minute (EPA 1994a)

S A_h_ = surface area of the extrathoracic region in humans = 200 cm^2^ (EPA 1994a)

As Table A-1 shows, the lowest LOAEL_HEC_ and NOAEL_HEC_ values were 6.6 and 3.3 ppm, respectively, for nasal epithelial degeneration and necrosis.

Selection of the Principal Study: Hotchkiss et al. (2010) conducted studies evaluating neurological and toxicological effects of 1,2-dichloroethane inhalation in rats. Hotchkiss et al. (2010) demonstrated a dose-response relationship between 1,2-dichloroethane exposure and degeneration of the nasal tissue. The LOAELHEC and NOAELHEC values for nasal lesions in the Hotchkiss et al. (2010) study were the lowest among the studies evaluating acute-duration exposure.

Summary of the Principal Study:

Hotchkiss JA, Andrus AK, Johnson KA, . 2010. Acute toxicologic and neurotoxic effects of inhaled 1,2-dichloroethane in adult Fischer 344 rats. Food Chem Toxicol 48(2):470–481. 10.1016/j.fct.2009.10.039.19887099

Fischer 344 rats were exposed to 0, 200, 600, or 2,000 ppm (or 0.0, 196.4, 607.8, and 2,029 ppm as analytically measured mean concentrations delivered) 1,2-dichloroethane for 4 hours or 0, 50, 100, or 150 ppm (or 0.0, 52.8, 107.5, and 155.8 ppm as analytically measured mean concentrations delivered) for 8 hours. Neurobehavioral and neuropathological effects were assessed using a functional observational battery and by light microscopy, respectively. Acute toxicological effects were assessed by bronchoalveolar lavage and histopathology of the respiratory tract and selected target organs. Neurobehavioral effects consistent with central nervous system depression were observed on day 1, but not at subsequent times (days 8 or 15). No neuropathological changes were reported. Degeneration/ necrosis of the olfactory epithelium was reported at an exposure of 107.5 ppm for 8 hours. Nasal regeneration occurred at 196.4 ppm (4-hour exposure). A decrease in adrenal, kidney, and liver weights occurred at an exposure concentration of 2,029 ppm for 4 hours.

Selection of the Point of Departure for the MRL: Benchmark dose (BMD) modeling was conducted to identify a point of departure (POD) using the data for degeneration/necrosis of nasal epithelium in rats administered 1,2-dichloroethane via inhalation for 8 hours. Combined male and female rat incidence data for nasal degeneration/necrosis were selected for BMD analysis (Table A-2) as the male and female data were deemed to be similar in their response. The data were fit to all available dichotomous models in EPA’s Benchmark Dose Software (BMDS, version 3.2.0.1) using a benchmark response (BMR) of 10% extra risk. Adequate model fit was judged by four criteria: goodness-of-fit statistics (p-value >0.1), visual inspection of the dose-response curve, a 95% confidence limit on the BMC (BMCL) that is not 10 times lower than the lowest non-zero dose, and scaled residual within ±2 units at the data point (except the control) closest to the predefined BMR. Among all of the models providing adequate fit to the data, the lowest BMCL was selected as the POD when the difference between the BMCLs estimated from these models was >3-fold; otherwise, the BMCL from the model with the lowest Akaike information criterion (AIC) was chosen. BMDS recommended the Multistage-3 model for nasal epithelium degeneration/ necrosis; however, this model yielded a BMCL (36.28 ppm) that was less than the experimental NOAEL (52.88 ppm) and three of four Multistage-3 model parameters were bounded. Evaluation of viable alternate models showed that the Log-Probit model derived a BMCL (57.62 ppm), similar to the experimental NOAEL (52.8 ppm), and provided a better fit than the Multistage 3-degree model with lower residuals near the BMC; therefore, the Log-Probit model was selected as the basis for estimating this MRL. The BMC/BMCL values considered for MRL derivation are presented in Table A-3 and the fit of the selected model is presented in Figure A-1.

Table A-2 Results from an 8-Hour Exposure to 1,2-Dichloroethane Via Inhalation and Subsequent Incidence of Nasal Epithelium Degeneration/Necrosis

Analytically measured mean concentration delivered (ppm) | Number (males and females) | Incidence of nasal epithelium degeneration/necrosis
Analytically measured mean concentration delivered (ppm) | Number (males and females)
Analytically measured mean concentration delivered (ppm) | Number (males and females) | Males | Females
0.0 | 10 | 0/5 | 0/5
52.8 | 10 | 0/5 | 0/5
107.5 | 10 | 1/5 | 3/5
155.8 | 10 | 4/5 | 5/5

Source: Hotchkiss et al. (2010)

Table A-3 Model Predictions for Increased Incidence of Nasal Epithelium Degeneration/Necrosis in Male and Female (Combined) Rats Following Inhalation Exposure to 1,2-Dichloroethane for 8 Hours (Hotchkiss et al. 2010)

| | | | | Scaled residuals^c^
Model | BMC_10_^a^ (ppm) | BMCL_10_^a^ (ppm) | p-Value^b^ | AIC | Dose below BMC | Dose above BMC
Dichotomous Hill | | | NA | 27.96 | −0.01 | 8.68×10^−5^
Gamma^d^ | 83.06 | 55.73 | 0.98 | 24.01 | −0.15 | 0.07
Log-Logistic^e^ | 84.68 | 57.42 | 0.83 | 26.04 | −0.19 | 0.07
Multistage Degree 3^f^ | 60.32 | 36.28 | 0.77 | 23.80 | −0.86 | −0.31
Multistage Degree 2^f^ | 42.87 | 25.40 | 0.36 | 26.87 | −0.0004 | −1.32
Multistage Degree 1^f^ | | | 0.02 | 34.86 | −0.0004 | −1.96
Weibull^d^ | 78.44 | 50.57 | 0.61 | 26.39 | −0.42 | 0.27
Logistic | 81.81 | 53.84 | 0.85 | 24.46 | −0.42 | 0.26
Log-Probit ^ g ^ | 84.32 | 57.62 | 0.997 | 23.97 | −0.08 | 0.02
Probit | 81.49 | 52.26 | 0.91 | 24.26 | −0.33 | 0.24

a BMC and BMCLs values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the BMC.

d Power restricted to ≥1.

e Slope restricted to ≥1.

f Betas restricted to ≥0.

g All models provided an adequate fit to the data except for the Dichotomous Hill and Multistage 1-degree models. BMCLs were sufficiently close (differed by <3-fold). The BMDS recommended the model with the lowest AIC (3-degree Multistage); however, three of the four parameters were bounded and the resulting BMCL (36.28) was lower than the experimental NOAEL (52.8 ppm). The Log-Probit model derived a BMCL value (57.62 ppm) similar to the experimental NOAEL and provided a better fit near the BMC with lower residuals; therefore, the Log-Probit model was selected.

AIC = Akaike Information Criterion; BMC = benchmark concentration (maximum likelihood estimate of the concentration associated with the selected benchmark response); BMCL_10_ = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., 10 = dose associated with 10% extra risk); BMDS = Benchmark Dose Software

Figure A-1 Fit of Log-Probit Model to Data on Incidence of Nasal Degeneration/Necrosis in Male and Female Rats (Combined) Administered 1,2-Dichloroethane via Inhalation for 8 Hours

Adjustment for Intermittent Exposure: The rats from the Hotchkiss et al. (2010) study were exposed for a total of 8 hours in a single day. Therefore, the BMCL_10_ was adjusted for intermittent exposure as follows:

B M C L_10 A D J_ = B M C L_10_ × (8 hours)/(24 hour) = 57.62 p p m × (8 hours)/(24 hours) = 19.21 p p m

Human Equivalent Concentration: The BMCL_10ADJ_ was converted to a HEC by multiplying the BMCL_10_ by the rat-specific regional gas dose ratio that corresponds with the extrathoracic region (RGDR_ET_), as nasal epithelium degeneration/necrosis is a localized-portal of entry effect (EPA 2012b). This RGDR_ET_ is calculated using the following equation as defined by EPA (1994a):

R G D R_E T_ = (V_E_a__)/(S A_a_) ÷ (V_E_h__)/(S A_h_)

- where:
- V_E_a__ = ventilation rate for male and female F344 rats = 0.211 L/minute (EPA 1994a)
- S A_a_ = surface area of the extrathoracic region in rats = 15 cm^2^ (EPA 1994a)
- V_E_h__ = ventilation rate for humans = 13.8 L/minute (EPA 1994a)
- S A_h_ = surface area of the extrathoracic region in humans = 200 cm^2^ (EPA 1994a)

Applying this equation results in an RGDR of 0.20 and the HEC was calculated as:

B M C L_10 H E C_ = B M C L_10 A D J_ × R G D R = 3.84 p p m

Uncertainty Factor: The BMCL_HEC_ is divided by a total uncertainty factor (UF) of 30:

- 3 for extrapolation from animals to humans after dosimetric adjustment
- 10 for human variability

This resulted in the following MRL:

M R L = (B M C L_H E C_)/(U F s) = (3.84 p p m)/(30) = 0.13 p p m , w h i c h r o u n d s t o 0.1 p p m

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Few studies of animals exposed to 1,3-dichloroethane by inhalation evaluated histopathology of the nasal turbinates. A chronic-duration study in rats exposed to 1,2-dichloroethane via inhalation also observed a NOAEL of 50 ppm for respiratory toxicity (Cheever et al. 1990). No histological alterations were observed in respiratory tracts, including nasal turbinates, of rats in this study. In another chronic-duration study, Nagano et al. (2006) evaluated a wide range of endpoints including clinical chemistry, hematology, gross pathology, organ weights, and histopathology; however, the publication does not specify the tissues examined for histopathology. The observation that the NOAELs were identical after acute- and chronic-duration exposure suggests that the nasal lesions may occur when exposure exceeds a concentration threshold.

Agency Contacts (Chemical Managers): Carolyn Harper, Ph.D.

## 1,2-Dichloroethane Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2-Dichloroethane
CAS Numbers: | 107-06-2
Date: | July 2024
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate
MRL: | 0.1 ppm (0.40 mg/m^3^)
Critical Effect: | Neurobehavioral changes (altered performance in open field test)
Reference: | Zhong et al. 2022
Point of Departure: | BBMCL_1SD_ of 14.8 ppm (BBMCL_HEC_ of 3.70 ppm)
Uncertainty Factor: | 30
LSE Graph Key: | 51
Species: | Mouse

MRL Summary: An intermediate-duration inhalation MRL of 0.1 ppm was derived for 1,2-dichloro-ethane based on altered performance in an open field test of male mice. Mice were exposed to ≤173 ppm 1,2-dichloroethane for 28 days at 6 hours/day, 7 days/week (Zhong et al. 2022). The MRL is based on a Bayesian benchmark response of 1 standard deviation (BBMCL_1SD_) of 14.8 ppm, which was adjusted to continuous duration exposure (6 hour/24 hour) and converted to a BBMCL_1SD-HEC_ of 3.70 ppm. The BBMCL_1SD-HEC_ of 3.70 ppm was divided by a total uncertainty factor of 30 (3 for extrapolation from animals to humans with dosimetric adjustment and 10 for human variability).

Selection of the Critical Effect: Review of the intermediate-duration inhalation database shows that the exposure level of 86 ppm is a serious LOAEL for neurological (Zhong et al. 2022) and male reproductive effects (Zhang et al. 2017). Therefore, to determine the critical effect for the intermediate-duration inhalation MRL, the POD must be <86 ppm. Studies with data meeting this criterion were considered for the critical effect (Table A-4).

The lowest exposure level evaluated in the intermediate-duration inhalation database was 25 ppm; this value is a NOAEL for both neurological effects and male reproductive effects. Neurological effects have been evaluated in numerous studies, identifying the neurological system as a target organ for 1,2-dichloroethane toxicity (details provided in Section 2.15). In contrast, male reproductive effects have only been evaluated in a single study (Zhang et al. 2017). Although results of the Zhang et al. (2017) show that 1,2-dichloroethane can produce serious effects to the testes, these findings have not been corroborated. Therefore, neurological effects, with the more extensive database, were identified as the critical effects for the intermediate-duration inhalation MRL (Liang et al. 2021; Zhong et al. 2022). Given that NOAELs for reproductive and neurological effect are the same (25 ppm), an MRL based on neurological effects should be protective of reproductive effects.

Table A-4 Summary of Possible Critical Effect for Derivation of the Intermediate-Duration Inhalation Exposure MRL for 1,2-Dichloroethane

Reference | Species | Exposure | Effect | NOAEL/LOAEL/SLOAEL
Liang et al. 2021 | Mouse | 28 days, 7 days/week, 6 hours/day (WB); 0, 25, 86, 173 ppm | Neurological: vacuolization in the cerebral cortex^a^ | NOAEL: 25 ppm; LOAEL: 86 ppm
Zhong et al. 2022 | Mouse | 28 days, 7 days/week, 6 hours/day (WB); 0, 25, 86, 173 ppm | Neurological: altered behavior in open field (decreased distance and time in central area); vacuolization and demyelination in the cerebral cortex | NOAEL: 25 ppm; SLOAEL: 86 ppm
Zhang et al. 2017 | Mouse | 28 days, 7 days/week, 6 hours/day (WB); 0, 25, 86, 173 ppm | Reproductive SLOAEL: histopathological alterations to the testes and dose-related increases in abnormal sperm | NOAEL: 25 ppm; SLOAEL: 86 ppm

a Behavioral effects and demyelination were not assessed.

LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; SLOAEL = serious lowest-observed-adverse-effect level; WB = whole-body exposure

Selection of the Principal Study: Neurological effects following intermediate-duration inhalation exposure to 1,2-dichloroethane were observed in studies by Zhong et al. (2022) and Liang et al. (2021), both with the same NOAEL value of 25 ppm. Results of open field tests by Zhong et al. (2022) showed decreased central distance/total distance (%) and decreased time in the central area of the test site; histopathological evaluations showed vacuolization and demyelination in the cerebral cortex at a concentration of 86 ppm. Taken together, these effects were considered to be a serious LOAEL. However, no neurological effects were observed at 25 ppm. Liang et al. (2021) reported increased vacuolization in the cerebral cortex at 86 ppm, with no effects at 25 ppm; neurobehavior was not evaluated in this study. Endpoints from both studies were further evaluated to determine the basis of the MRL. As discussed below, further analyses identified the lowest POD for central distance/total distance (%). Therefore, Zhong et al. (2022) was selected as the principal study.

Summary of the Principal Study:

Zhong, Y, Liang, B, Meng H, . 2022. 1,2-Dichloroethane induces cortex demyelination by depressing myelin basic protein via inhibiting aquaporin 4 in mice. Ecotoxicol Environ Saf 231:113180.35026584

Groups of 20 male CD-1 mice were exposed to 0, 25, 86, and 173 ppm 1,2-dichloroethane (whole body) for 6 hours/day for 28 consecutive days. In addition to CD-1 mice, the experiments also included aquaporin 4 knock-out mice to provide mechanistic data (not discussed in this summary). After the last exposure, mice were evaluated in open field tests for total distance traveled, distance traveled in the central area relative to the total distance traveled (%), time spent in the central area, and mean speed. Additional assessments included histopathological examination of the cerebral cortex and brain-water content measurement from five additional mice exposed under the same conditions.

Results of open field tests showed dose-dependent decreases in the distance traveled in the central area relative to the total distance traveled and time spent in the central area in mice exposed to 86 and 173 ppm; no decreases were observed relative to control at 25 ppm. The total distance traveled was decreased in mice exposed to 173 ppm, but not at 25 or 86 ppm. Mean speed was similar between controls and the three treatment groups. Histopathological examination of the cerebral cortex found dose-related increases in vacuolization and demyelination in mice exposed to 86 and 173 ppm. Brain water content was increased in the 173-ppm group. Based on results of this study, the NOAEL and SLOAEL were identified as 25 and 86 ppm, respectively.

Selection of the Point of Departure for the MRL: Neurological effects data from the Zhong et al. (2022) and Liang et al. (2021) studies were considered as the possible basis for derivation of the intermediate-duration inhalation MRL. Data sets for distance traveled in the central area relative to the total distance traveled, mean time in the central area, and vacuolization in the cerebral cortex are summarized in Table A-5. All data were presented graphically; therefore, GrabIt^®^ software was used to convert graphic data to numeric data.

Table A-5 Data Considered as the Critical Effect for the Intermediate-Duration Inhalation MRL

Reference | Endpoint | Number | Exposure concentration (ppm)
Reference | Endpoint | Number | 0 | 25 | 86 | 173
Liang et. al 2021 | Vacuolization area cerebral cortex (%) | 5 | 21.39±1.18^a^ | 21.98±0.59 | 29.11±1.19^b^ | 34.46±0.59^b^
Zhong et al. 2022 | Central distance/total distance (%) | 20 | 18.71±7.74 | 12.9±5.81 | 9.35±5.81^b^ | 6.13±3.71^b^
Zhong et al. 2022 | Mean time in the central area (seconds) | 20 | 36.99±23.23 | 25.81±12.9 | 13.76±15.49^b^ | 9.46±4.3^b^
Zhong et al. 2022 | Vacuolization area cerebral cortex (%) | 5 | 1.81±0.82 | 2.13±0.89 | 5.00±1.07^b^ | 5.6±1.09^b^

a Values are mean±standard deviation; estimated from graphically presented data using GrabIt! or Digitizelt 2.5.9 Software.

b ANOVA and LSD multiple comparison test, p<0.05.

ANOVA = analysis of variance; LSD = least significant difference

All data sets were modeled using EPA’s Benchmark Dose Software (BMDS, version 3.2.0.1). None of the models for these endpoints provided adequate fit. Therefore, data were run using the Bayesian Benchmark Dose (BBMD) modeling online software [Bayesian BMD (benchmarkdose.com)]. Data for distance/total distance and mean time in central area were fitted to all continuous models using a BBMCL_1SD_. Data for vacuolization were also fitted to all continuous models but used a Bayesian benchmark response of 10% relative deviation (BBMCL_10%RD_). To obtain a model averages, Bayesian benchmark concentration (BBMC) weighted the Exponential 2, Exponential 3, Exponential 4, Exponential 5, Hill, Power, Michaelis-Menten, and linear models equally (i.e., 12.5% each) as recommended by EPA (2020b). The resulting average BBMCL_1SD_ values for distance/total distance and mean time in central area were 14.763 and 20.073 ppm, respectively, and the BBMCL_10%RD_ for vacuolization data obtained for Liang et al. (2021) was 15.523 ppm. Vacuolization data from Zhong et al. (2022) could not be appropriately modeled because of the wide uncertainty on each of the dose groups which was due to the small response, small sample size (n=5), and high variability between the animals. ATSDR considered the NOAEL of 25 ppm for Zhong et al. (2022) vacuolization data for a potential POD. However, the lowest model-averaged BBMCL value of 14.763 ppm for central distance/total distance (%) was selected as the POD. The posterior model probabilities were 0.318, 0.0.83, 0.284, 0.052, 0.069, 0.016, 0.110, and 0.07 for the Exponential 2, Exponential 3, Exponential 4, Exponential 5, Hill, Power, Michaelis-Menten, and linear models, respectively (Table A-6). Model results are presented graphical in Figure A-2.

Adjustment for Intermittent Exposure: Mice in the Zhong et al. (2022) study were exposed for 6 hours/day for 28 consecutive days. Therefore, the BBMCL_1SD_ was adjusted for intermittent exposure as follows:

B B M C L_A D J_ = B B M C L_1 S D_ × (6 hours)/(24 hours) = 14.8 p p m × (6 hours)/(24 hours) = 3.70 p p m

Human Equivalent Concentration: For systemic (extrarespiratory) effects, the HEC is calculated by multiplying the duration-adjusted animal BBMCL_ADJ_ by the ratio of the blood:gas partition coefficients in animals and humans. Gargas et al. (1989) estimated a blood:air partition coefficient of 19.5±0.7 for 1,2-dichloroethane in humans; however, a blood:air partition coefficient for mice was not located. Therefore, the default value of 1 was used for the ratio, resulting in the BBMCL_HEC_ of 3.70 ppm.

Uncertainty Factor: The BBMCL_HEC_ was divided by a total uncertainty factor (UF) of 30:

- 3 for extrapolation from animals to humans after dosimetric adjustment
- 10 for human variability

This results in the following MRL:

M R L = (B B M C L_H E C_)/(U F s) = (3.70 p p m)/(30) = 0.123 p p m , w h i c h r o u n d s t o 0.1 p p m

Other Additional Studies or Pertinent Information that Lend Support to this MRL: The intermediate-duration inhalation oral MRL is based on neurological effects identified in open field tests. ATSDR considers results of open field and maze tests to be valid indicators of adverse neurological effects and has used results from these tests to derive MRLs for other chemicals (e.g., 1-bromopropane, bromomethane, cypermethrin, permethrin, and fuel oil #2). Studies in humans and animals identify the neurological system as a target for inhaled 1,2-dichloroethane. In animals, acute- and intermediate-duration inhalation exposure studies have observed neurological effects. Acute effects of inhalation exposure have been observed at concentrations of 111‒1,235 ppm; effects include decreased motor activity and response to stimuli (Hotchkiss et al. 2010; Wang et al. 2013; Yang et al. 2021), tremor (Jin et al. 2018a, 2018b, 2019), cerebral edema (Jin et al. 2019; Zhang et al. 2011), vacuolization in the cerebral cortex (Zhong et al. 2020), and brain lesions (Zhou et al. 2016). For intermediate-duration exposure, in addition to neurological effects observed at 86 ppm (Liang et al. 2021; Zhong et al. 2022), damage to cerebellar granular cells (shrunken and hypereosinophilic cytoplasm, nuclear pyknosis, apoptosis) was observed at approximately 180 ppm (Huang et al. 2020).

Relevance of neurological effects observed in animals to humans is supported by numerous case reports of individuals who inhaled 1,2-dichloroethane (Chen et al. 2015, Dang et al. 2019; Liu et al. 2010; Zhan et al. 2011). Effects included drowsiness, delirium, and headache; tremors; slow response to verbal commands; encephalopathy and cerebral edema; and neuronal necrosis and white matter demyelination. Autopsies of individuals who died following exposure showed morphological alterations in the nervous system including vascular disorders, diffuse changes in cerebellar cells, parenchymatous changes in the brain and spinal cord, myelin degeneration, and hyperemia, swelling, edema, and hemorrhage of the brain (Hubbs and Prusmack 1955; Hueper and Smith 1935; Lochhead and Close 1951). An occupational exposure study in 221 workers reported impaired attention, nonverbal processing speed, verbal memory and learning, and motor strength and speed (Bowler et al. 2003). Reliable exposure estimates for 1,2-dichloroethane in humans were not reported.

Table A-6 BBMD Model Predictions for Central Distance/Total Distance (%) in Male Mice Following 28-Day Inhalation Exposure to 1,2-Dichloroethane (Zhong et al. 2022)

Statistic | Model average | Exponential 2 | Exponential 3 | Exponential 4 | Exponential 5 | Hill | Power | Michaelis Menten | Linear
Prior model weight | N/A | 0.125 | 0.125 | 0.125 | 0.125 | 0.125 | 0.125 | 0.125 | 0.125
Posterior model weight | N/A | 0.312 | 0.080 | 0.284 | 0.053 | 0.065 | 0.015 | 0.126 | 0.065
Fraction with BMDs | 99.7% | 100.0% | 100.0% | 99.5% | 97.0% | 99.6% | 100.0% | 100.0% | 100.0%
BMD (median) | 55.814 | 58.347 | 72.517 | 29.552 | 24.197 | 75.847 | 109.656 | 79.796 | 93.986
BMDL (5^th^ percentile) | 14.763 | 38.897 | 46.033 | 9.588 | 2.105 | 21.876 | 81.229 | 35.408 | 72.990
25^th^ percentile | 34.964 | 49.106 | 59.691 | 20.606 | 6.994 | 39.699 | 96.090 | 63.696 | 84.162
Mean (SD) | 59.101 (32.913) | 61.845 (18.584) | 76.768 (23.704) | 33.172 (19.079) | 22.044 (15.871) | 74.517 (39.174) | 113.655 (24.152) | 81.165 (29.207) | 97.483 (19.388)
75^th^ percentile | 79.044 | 70.683 | 89.736 | 42.112 | 27.497 | 100.076 | 127.109 | 96.015 | 107.108
95^th^ percentile | 114.375 | 96.155 | 121.097 | 67.658 | 49.466 | 136.830 | 161.300 | 130.349 | 132.593

BBMD = Bayesian benchmark dose; BMD = benchmark dose; BMDL = lower confidence limit on the BMD; SD = standard deviation

Figure A-2 Bayesian Benchmark Dose (BBMD) Model Predictions for Central Distance/Total Distance (%) in Male Mice Following 28-Day Inhalation Exposure to 1,2-Dichloroethane (Zhong et al. 2022)

Agency Contacts (Chemical Managers): Carolyn Harper, Ph.D.

## 1,2-Dichloroethane Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2-Dichloroethane
CAS Numbers: | 107-06-2
Date: | July 2024
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL. The two available studies identified effect levels (LOAELs and NOAELs) for noncancer effects that are higher than both the POD for the acute-duration inhalation MRL (36.28 ppm) and the serious LOAEL for intermediate-duration inhalation exposure (25 ppm), precluding derivation of an MRL.

Rationale for Not Deriving an MRL: An MRL has not been derived for chronic-duration inhalation exposure to 1,2-dichloroethane. As summarized in Table A-7, there are only two studies that investigate the effects of chronic-duration inhalation exposure to 1,2-dichloroethane. Cheever et al. (1990) monitored for a number of health effects in rats exposed to 50 ppm of 1,2-dichloroethane for 7 hours/day, 5 days/week, for 2 years. No increased cancer incidences were observed, and the only noncancer effect noted was an increased incidence of unspecified testicular lesions (24 versus 10% in controls) observed at gross necropsy. Histopathology examination did not show increased incidences of testicular lesions. Nagano et al. (2006) found significantly increased tumor incidences in rats and mice exposed to 1,2-dichloroethane for 6 hours/day, 5 days/week, for 104 weeks, but did not report any noncancer effects, resulting in freestanding noncancer NOAELs of 160 and 90 ppm in rats and mice, respectively. All of the available effect levels are higher than the POD used for derivation of the acute-duration inhalation MRL (36.28 ppm) and the serious LOAEL of 25 ppm for sperm abnormalities in mice exposed for 4 weeks (Zhang et al. 2017). Neither Cheever et al. (1990) nor Nagano et al. (2006) evaluated sperm parameters. Therefore, a chronic-duration MRL could not be derived.

Table A-7 Summary of Relevant NOAEL and LOAEL Values Following Chronic-Duration Inhalation Exposure to 1,2-Dichloroethane

Species | Duration | NOAEL (NOAEL_ADJ_)^a^ (ppm) | LOAEL (LOAEL_ADJ_)^a^ (ppm) | Effect | Reference
Rat Sprague-Dawley | 7 hours/day; 5 days/week; 2 years | | 50 (10) | Increased testicular lesions (not further specified) | Cheever et al. 1990
Rat Fischer 344 | 6 hours/day; 5 days/week; 104 weeks | 160 (28.6) | | NOAEL without LOAEL | Nagano et al. 2006
Mouse B6D2F1 | 6 hours/day; 5 days/week; 104 weeks | 90 (16) | | NOAEL without LOAEL | Nagano et al. 2006

a Adjusted daily dose = I n t e r m i t t e n t d o s e × (Exposure hours)/(24 hours) × (Exposure days)/(7 days)

ADJ = adjusted; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level

Agency Contacts (Chemical Managers: Carolyn Harper, Ph.D.

## 1,2-Dichloroethane Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2-Dichloroethane
CAS Numbers: | 107-06-2
Date: | July 2024
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: The available data are insufficient for derivation of an acute-duration oral MRL for 1,2-dichloroethane.

Rationale for not deriving an MRL: The database of acute-duration oral toxicity studies of 1,2-dichloro-ethane consists of one 14-day study in rats (van Esch et al. 1977), one 14-day study in mice (Munson et al. 1982), one 14-day developmental toxicity study in rats (Payan et al. 1995), one 10-day study in rats (Daniel et al. 1994), and two lethality studies (McCollister et al. 1956; Munson et al. 1982). With limited data reporting, the lethality studies were excluded from consideration. All of the remaining studies used gavage administration. Van Esch et al. (1977) identified hepatic effects of fatty degeneration in rats at 300 mg/kg/day, the same dose at which 100% mortality occurred. In the study by Daniel et al. (1994), due to high mortality in the 300 mg/kg/day group, the highest dose evaluated was 100 mg/kg/day. Inflammation of the forestomach was observed at 100 mg/kg/day. No other effects were reported in Daniel et al. (1994). In the developmental toxicity study (Payan et al. 1995), a LOAEL of 198 mg/kg/day was identified for decreased maternal weight gain. The lowest dose from an acute-duration study was in Munson et al. (1982). Mice were administered doses of 0, 4.9, or 49 mg/kg/day for 14 days. The lowest dose at which an effect was observed was a LOAEL of 4.9 mg/kg/day based on reduced humoral and cell-mediated immune responses (Munson et al. 1982). As the LOAEL was the lowest dose tested, no NOAEL was determined. Male mice had a dose-related reduction in humoral immune response (IgM response to sheep erythrocytes). The number of antibody-forming cells (AFCs) were reduced in a dose-related manner, significant at both doses, and adjusted AFC/106 cells were reduced in a dose-related manner, significant at 49 mg/kg/day. Cell-mediated immune response (delayed-type hypersensitivity response to sheep erythrocytes) was significantly reduced in both dose groups but was not dose-related. Decreased serum leukocytes were observed at 49 mg/kg/day.

As Munson et al. (1982) was a gavage study, it is important to emphasize that there is a notable difference in toxicokinetics between gavage and drinking water administration (see Section 3.1). With gavage administration, bolus dosing leads to saturation of the detoxification/excretion mechanism and exacerbates toxicity. In an intermediate-duration, 90-day study by the same study authors, mice administered up to 189 mg/kg/day 1,2-dichloroethane in the drinking water did not exhibit immune suppression (Munson et al. 1982). As the critical effect from the acute-duration gavage study was not observed at higher doses in the drinking water, it is not appropriate to derive an acute-duration oral MRL.

Agency Contacts (Chemical Managers): Carolyn Harper, Ph.D.

## 1,2-Dichloroethane Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2-Dichloroethane
CAS Numbers: | 107-06-2
Date: | July 2024
Profile Status: | Final
Route: | Oral
Duration: | Intermediate
MRL: | 0.7 mg/kg/day
Critical Effect: | Kidney tubule regeneration, increased kidney weight
References: | Morgan et al. 1990; NTP 1991
Point of Departure: | BMDL_10_ 70.08 mg/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 10
Species: | Rat

MRL Summary: An intermediate-duration oral MRL of 0.7 mg/kg/day was derived for 1,2-dichloro-ethane based on an increase in kidney lesions (tubule regeneration) in rats administered 1,2-dichloro-ethane via drinking water (Morgan et al. 1990; NTP 1991). The MRL is based on a BMDL_10_ of 70.08 mg/kg/day and a total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

Selection of the Critical Effect: A number of studies have evaluated the toxicity of 1,2-dichloroethane following intermediate-duration oral exposure; these studies examined a wide range of endpoints including kidney and liver effects (Alumot et al. 1976; Cottalasso et al. 2002; Daniel et al. 1994; Morgan et al. 1990; Munson et al. 1982; NTP 1991; van Esch et al. 1977), neurotoxicity (Daniel et al. 1994; Morgan et al. 1990; NTP 1991; van Esch et al. 1977), gastrointestinal toxicity (Morgan et al. 1990; NTP 1991; van Esch et al. 1977), hematotoxicity (Daniel et al. 1994; Morgan et al. 1990; Munson et al. 1982; NTP 1991; van Esch et al. 1977), and reproductive toxicity (Charlap 2015; Daniel et al. 1994; Lane et al. 1982; Morgan et al. 1990; NTP 1991; van Esch et al. 1977). The LOAELs for these studies range from 75 to 448 mg/kg/day.

The available data suggest that nephrotoxicity is the most sensitive endpoint following intermediate-duration oral exposure. The lowest LOAELs and NOAELs for renal effects are shown in Table A-8. In female F344/N rats exposed via drinking water, increased absolute and relative kidney weights and renal tubule degeneration were observed at doses >102 mg/kg/day (Morgan et al. 1990; NTP 1991). Increased relative kidney weight was also seen in rats treated with 75 or 90 mg/kg/day by gavage for 90 days (Daniel et al. 1994; NTP 1991; van Esch et al. 1977); however, it is important to emphasize that there is a notable difference in toxicokinetics between gavage and drinking water administration (see Section 3.1). With gavage administration, bolus dosing leads to saturation of the detoxification/excretion mechanism and exacerbates toxicity. Renal effects (e.g., increased kidney weight and/or histopathological lesions) were also found in in mice exposed via drinking water at doses >448 mg/kg/day and in rats following acute- and intermediate-duration inhalation exposure (Heppel et al. 1946; Hotchkiss et al. 2010; Morgan et al. 1990; NTP 1991; Spencer et al. 1951).

Table A-8 Summary of NOAEL and LOAEL Values for Sensitive Targets of Intermediate-Duration Drinking Water Exposure to 1,2-Dichloroethane

Species | Duration | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Renal effects
F344 rat | 13 weeks; 7 days/week | 58 F | 102 F | Tubular regeneration, increase in absolute and relative kidney weight | Morgan et al. 1990; NTP 1991
CD-1 mouse | 90 days | 189 | ND | None | Munson et al. 1982
B6C3F1 mouse | 13 weeks; 7 d/week | 249 | 448 | Tubular regeneration, increased absolute and relative kidney weight | Morgan et al. 1990; NTP 1991
Sprague-Dawley rat | 1-generation; (90–120 days); 7 days/week | 300 | ND | None | Charlap 2015
Sprague-Dawley rat | 13 weeks; 7 days/week | 531 | ND | None | Morgan et al. 1990; NTP 1991
Osborne-Mendel rat | 13 weeks; 7 days/week | 727 | ND | None | Morgan et al. 1990; NTP 1991
Body weight effects
Osborne-Mendel rat | 13 weeks; 7 days/week | 126 M | 266 M | 12% decrease in terminal body weight of males | Morgan et al. 1990; NTP 1991
Sprague-Dawley rat | 1-generation; (90–120 days) | 150 M | 300 M | Decreased body weight by 10% | Charlap 2015
Sprague-Dawley rat | 13 weeks; 7 days/week | 531 | ND | None | Morgan et al. 1990; NTP 1991
F344 rat | 13 weeks; 7 days/week | 601 | ND | None | Morgan et al. 1990; NTP 1991
B6C3F1 mouse | 13 weeks; 7 days/week | 2,710 M | 4,207 M | 16% decrease in terminal body weight | Morgan et al. 1990; NTP 1991

F = female(s); LOAEL = lowest-observed-adverse-effect level; M = male(s); ND = not determined; NOAEL = noobserved-adverse-effect level

Alumot et al. (1976) reported increased fat content in the livers of rats exposed via feed at a dose of 80 mg/kg/day for 7 weeks. However no hepatic effects were seen in rats or mice at much higher doses and for longer durations in the remaining studies (Charlap 2015; Daniel et al. 1994; Morgan et al. 1990; NTP 1991; van Esch et al. 1977; Munson et al. 1982); thus, hepatic effects were not considered for use in MRL derivation.

Body weight effects were reported in several drinking water studies of 1,2-dichloroethane, as shown in Table A-9. The lowest LOAEL for body weight effects in a drinking water study was 266 mg/kg/day in the 13-week study of Osborne-Mendel rats (Morgan et al. 1990; NTP 1991). This LOAEL is higher than the LOAEL of 102 mg/kg/day for renal effects in F344 rats exposed by drinking water; therefore, renal effects were selected as the critical effect.

Selection of the Principal Study: F344/N rats, Sprague-Dawley rats, Osborne-Mendel rats, and B6C3F1 mice were exposed to drinking water containing 1,2-dichloroethane (Morgan et al. 1990; NTP 1991). Dose-related effects on the kidney (i.e., increased weight and renal tubule regeneration) were observed in female F344/N rats and male B6C3F1 mice only. Rats were more sensitive to these effects than mice, with significantly lower NOAEL and LOAEL values; therefore, the drinking water experiment in F344/N rats was selected as the principal study.

Summary of the Principal Studies:

Morgan DL, Bucher JR, Elwell MR. 1990. Comparative toxicity of ethylene dichloride in F344/N, Sprague-Dawley and Osborne-Mendel rats. Food Chem Toxicol 28(12):839–845.2276705

NTP. 1991. NTP technical report on the toxicity studies of 1,2-dichloroethane (ethylene dichloride) in F344/N rats, Sprague Dawley rats, Osborne-Mendel rats, and B6C3F1 mice (drinking water and gavage studies) (CAS No. 107–06-2). Research Triangle Park, NC: National Toxicology Program. NTP Tox 4. NIH Publication No. 91–3123.

Groups of F344/N rats (10 /sex) were exposed to drinking water containing 0, 500, 1,000, 2,000, 4,000, or 8,000 ppm of 1,2-dichloroethane for 13 weeks. The high concentration was close to the solubility limit for 1,2-dichloroethane in water. Reported estimates of intake from the water were 0, 49, 86, 147, 259, and 515 mg/kg/day in male rats and 0, 58, 102, 182, 320, and 601 mg/kg/day in female rats. Signs of toxicity, body weight, food and water consumption, hematology, and serum chemistry were evaluated throughout the study, and comprehensive gross and histological examinations were performed at the end of the exposure period.

Dose-related decreased water consumption occurred in both sexes. There was >10% reduction in body weight gain at 259 mg/kg/day in male F344/N rats. There were no significant reductions in body weight gain in female rats. In female rats, absolute and relative kidney weights were increased at doses >102 mg/kg/day. Renal tubular regeneration, described as one or more foci of basophilic-staining tubules lined by closely packed tubular epithelium in the cortex or outer medulla (minimal-to-mild in severity), was observed in female rats administered 601 mg/kg/day. Thus, dose-related changes in kidney weight were not correlated with renal lesions. Absolute and relative kidney weight increases were also observed in male rats at doses >86 mg/kg/day; however, the dose-related change in organ weight was not correlated with renal lesions, which occurred in 9/10 rats in all groups including controls. No effects were observed in other organs of male or female rats.

Selection of the Point of Departure for the MRL: BMD modeling was conducted to identify a POD using the kidney weight and histopathological lesion data from female rats in the drinking water study (see Table A-9).

Table A-9 Kidney Weights and Incidence of Tubule Regeneration in Female F344 Rats Exposed to 1,2-Dichloroethane in Drinking Water for 13 Weeks

Dose (mg/kg/day) | 0 | 58 | 102 | 182 | 320 | 601
Body weight (% of control) | | 101 | 102 | 99 | 97 | 93
Water intake (g/day) | 19 | 18 | 16 | 14 | 12 | 11
Absolute kidney weight^a^ (mg) | 739±26 | 814±16^b^ (↑10) | 885±16^c^ (↑20) | 845±17^c^ (↑14) | 932±15^c^ (↑26) | 923±15^c^ (↑25)
Relative kidney weight^a^ (%) | 3.8±0.13 | 4.1±0.07 (↑8%) | 4.2±0.17^b^ (↑11%) | 4.3±0.07^c ^(↑13%) | 4.8±0.09^c^ (↑26%) | 5.0±0.04^c^ (↑32%)
Tubule regeneration^d^ | 0/10 | 0/10 | 1/10 | 2/10 | 3/10 | 9/10^c^

a Organ weights reported as mean±standard error; n=10.

b p<0.5.

c p<0.01.

d Tubule regeneration was characterized as one or more foci of basophilic-staining tubules lined by closely packed tubular epithelium in the cortex or outer medulla of the kidney of minimal-to-mild severity.

Source; NTP (1991)

BMD modeling of dichotomous data (renal lesions in Female F344 rats) was conducted with EPA’s BMDS (version 3.2.0.1). For these data, the Dichotomous Hill, Gamma, Logistic, Log Logistic, Log Probit, Multistage, Probit, and Weibull dichotomous models available within the software were fit using a BMR of 10% extra risk. Adequacy of model fit was judged by four criteria: the χ2 goodness-of-fit p-value (p>0.1), magnitude of scaled residuals for the dose group nearest to the BMD (absolute value <2.0), BMDL that is not 10 times lower than the lowest non-zero dose, and visual inspection of the model fit. Among all models providing adequate fit, the BMDL from the model with the lowest AIC is selected as a potential POD if the BMDLs are sufficiently close (<3-fold); if the BMDLs are not sufficiently close (>3-fold), model-dependence is indicated, and the model with the lowest reliable BMDL is selected. All models provided an adequate fit to the data (χ2 goodness-of-fit p-value >0.1). The BMDLs were marginally over the 3-fold difference (~3.1-fold) suggested rule; therefore, the model with the lowest BMDL (1-degree Multistage model) was recommended by the BMDS. Visual inspection of the dose-response of the 1-degree Multistage model, however, indicates that there is a poor visual fit in the low-dose region of the predicted curve. A poorer fit is also indicated by the scaled residual near the BMD of -1.03, which is higher when compared to the viable alternative models. Because the difference in BMDLs was marginally close and because there was a relatively poor visual fit of the 1-degree Multistage model in the low-dose region of the curve, the model with the lowest AIC was chosen as a viable alternative (2-degree Multistage). The predicted BMD_10_ and BMDL_10_ values for this dataset are 139.26 and 70.08 mg/kg-day, respectively (see Table A-10 and Figure A-3).

Table A-10 Model Predictions for Increased Incidence of Renal Lesions in Female F344 Rats Following Exposure to 1,2-Dichloroethane in Drinking Water for 13 Weeks (NTP 1991)

| | | | | Scaled residuals^c^
Model | BMD10^a^ (mg/kg/day) | BMDL_10_^a^ (mg/kg/day) | p-Value^b^ | AIC | Dose below BMD | Dose above BMD
Dichotomous Hill | 142.02 | 80.55 | 0.29 | 45.75 | 0.81 | 0.24
Gamma^d,e^ | 138.68 | 75.97 | 0.75 | 41.23 | 0.72 | 0.21
Log-Logistic^e^ | 142.02 | 80.55 | 0.66 | 41.75 | 0.81 | 0.24
Multistage Degree 5^f^ | 131.14 | 59.37 | 0.86 | 42.34 | 0.32 | 0.42
Multistage Degree 4^f^ | 132.74 | 61.03 | 0.84 | 42.42 | 0.33 | 0.45
Multistage Degree 3^f^ | 137.24 | 64.48 | 0.80 | 42.55 | 0.39 | 0.46
Multistage Degree 2 ^f,g^ | 139.26 | 70.08 | 0.83 | 40.83 | 0.62 | 0.30
Multistage Degree 1^f^ | 61.10 | 40.50 | 0.28 | 45.91 | −1.03 | −0.53
Weibull^d^ | 142.44 | 77.67 | 0.68 | 42.82 | 0.69 | 0.35
Logistic | 178.79 | 124.15 | 0.81 | 41.34 | 0.52 | 0.73
Log-Probit | 135.39 | 81.04 | 0.45 | 43.90 | 0.82 | 0.04
Probit | 166.93 | 115.93 | 0.84 | 41.08 | 0.57 | 0.64

a BMD and BMDL values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the BMD.

d Power restricted to ≥1.

e Slope restricted to ≥1.

f Betas restricted to ≥0.

g Recommended model. All models provided adequate fit to the data. The BMDLs were marginally >3-fold; however, the model with the lowest BMDL (1-degree Multistage) provided a relatively poor fit to the low-dose region of the curve. After exclusion of the 1-degree Multistage model, the remaining BMDLs were within 3-fold; therefore, the model with the lowest AIC was selected (2-degree Multistage).

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _10_ = dose associated with 10% extra risk)

Figure A-3 Fit of 2-Degree Multistage Model to Incidence Data for Renal Lesions in Female F344 Rats Following Exposure to 1,2-Dichloroethane in Drinking Water for 13 Weeks (NTP 1991)

BMD modeling of continuous data (absolute and relative kidney weight) was conducted with the EPA’s BMDS (version 3.2.0.1). For these data, the Exponential, Hill, Linear, Polynomial, and Power continuous models available within the software were fit employing a BMR of 1 standard deviation (SD). An adequate fit was judged based on the χ2 goodness-of-fit p value (p>0.1), magnitude of the scaled residuals in the vicinity of the BMR, and visual inspection of the model fit. In addition to these three criteria for judging adequacy of model fit, a determination was made as to whether the variance across dose groups was constant. If a constant variance model was deemed appropriate based on the statistical test provided in BMDS (i.e., Test 2; p-value >0.1), the final BMD results were estimated from a constant variance model. If the test for homogeneity of variance was rejected (p-value <0.1), the model was run again while modeling the variance as a power function of the mean to account for this nonconstant variance. If this nonconstant variance model did not adequately fit the data (i.e., Test 3; p-value <0.1), the data set was considered unsuitable for BMD modeling. Among all models providing adequate fit, the lowest BMDL was selected if the BMDLs estimated from different models varied >3-fold; otherwise, the BMDL from the model with the lowest AIC was selected. For absolute kidney weight, the constant variance model provided an adequate fit to the full dataset; however, none of the models provided adequate fit to the means (p-value <0.1). For relative kidney weight, neither the constant variance nor the nonconstant variance model provided an adequate fit to the variance data. Therefore, the kidney weight datasets were not amenable to BMD modeling.

The selected POD for intermediate-duration oral exposure was the BMDL_10_ value of 70.08 mg/kg/day for renal lesions (tubule regeneration) in female rats.

Adjustment for Intermittent Exposure: Not applicable.

Uncertainty Factor: The BMLD_10_ of 70.08 mg/kg/day was divided by a total uncertainty factor (UF) of 100 (10 for human variability and 10 for extrapolation from animals to humans.

- 10 for extrapolation from animals to humans
- 10 for human variability

This resulted in the following MRL:

- MRL = BMLD_10_ ÷ UF
- MRL = 70.08 mg/kg/day ÷ (10×10) = 0.7 mg/kg/day

Other Additional Studies or Pertinent Information: Renal effects (e.g., increased kidney weight and/or tubular epithelial regeneration) were also found in mice exposed via drinking water at doses >448 mg/kg/day and in animals following acute- and intermediate-duration inhalation exposure (Heppel et al. 1946; Hotchkiss et al. 2010; Spencer et al. 1951) and intermediate-duration dermal exposure (Suguro et al. 2017).

Agency Contacts (Chemical Managers): Carolyn Harper, Ph.D.

## 1,2-Dichloroethane Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2-Dichloroethane
CAS Numbers: | 107-06-2
Date: | July 2024
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: The available data are insufficient for derivation of a chronic-duration oral MRL for 1,2-Dichloroethane.

Rationale for not deriving an MRL: The database of chronic-duration oral toxicity studies for 1,2-dichloroethane consists of one 2-year dietary study in rats (Alumot et al. 1976) and one 78-week gavage study in rats and mice (NCI 1978). Alumot et al. (1976) administered doses of 0, 12.5, or 25 mg/kg/day in feed to rats for 2 years. No effects were observed for any endpoint. This study had several significant limitations including unknown purity of the compound, unclear concentrations of 1,2-dichloroethane in the mash diet and dose consumed, and absence of gross or histological examination of organs or tissues. NCI (1978) administered 1,2-dichloroethane to Osborne-Mendel rats at doses of 0, 47, and 95 mg/kg/day and B6C3F1 mice at doses of 0, 97, and 195 (males) and 0, 149, and 299 mg/kg/day (females) via gavage on 5 days/week for 78 weeks. There was high mortality at the high dose in rats of both sexes and in female mice. The only other health effect observed was cancer. Limitations of the NCI (1978) study include dosage adjustments throughout the exposure period, high mortality, and fewer control animals (20/sex) than exposed (50/sex). Both available studies are via the gavage route, and it is important to emphasize that there is a notable difference in toxicokinetics between gavage and drinking water administration (see Section 3.1). With gavage administration, bolus dosing leads to saturation of the detoxification/excretion mechanism and exacerbates toxicity. Due to the limitations, route, and the fact that the only observed effects were death and cancer, available data were not considered adequate for use in deriving an MRL.

Agency Contacts (Chemical Managers): Carolyn Harper, Ph.D.