# CHAPTER 8 REFERENCES

* Cited in text

*Abdel-Kader MHK, Peach ME, Stiles DA. 1979. Determination of ethylene dibromide in fortified soils by molecular emission cavity analysis using a modified extraction process. J Assoc Off Anal Chem 62:114–118.
ACGIH. 1987–1988. TLV’s - Threshold limited values and biological indices for 1987-1988. Cincinnati, OH: American Conference of Governmental Industrial Hygienists, 21.
Adams PM, Legator MS, Fanini D. 1983. The effect of paternal exposure to ethylene dibromide on the behavior of the F1 progeny [Abstract]. Teratology 27:27A.
*Adkins B Jr, Van Stee EW, Simmons JE, 1986. Oncogenic response of strain A/J mice to inhaled chemicals. J Toxicol Environ Health 17:311–322.3083111
*Akamine EK. 1952. Toxicity of ethylene dibromide to white rats. Hawaii Agricultural Experiment Station of the University of Hawaii, Progress Notes No. 83, July 1984, 1–4.
*Alavanja MCR, Blair A, Masters M. 1988. Mortality study of workers in the grain industry [Abstract]. Am J Epidemiol 128:900.
*Albano E, Poli G, Tomasi A, 1984. Toxicity of 1,2-dibromoethane in isolated hepatocytes: Role of lipid peroxidation. Chem Biol Interact 50:255–266.6378412
*Alleman TG, Sanders RA, Madison BL. 1986. Simultaneous analysis of grain and grain-based products for ethylene dibromide, carbon tetrachloride, and ethylene dichloride. J Assoc Off Anal Chem 69:575–580.3528116
Alumot E, Chalutz E. 1972. Fumigation of citrus fruit with ethylene dibromide. Desorption of residues and ethylene evolution. Pestic Sci 3:539–544.
Aman J, Farkas L, Ben-Shamai MH, 1946. Experiments on the use of ethylene dibromide as a fumigant for grain and seed. Ann Appl Biol 33:389–395.
*Ames BN, Yanofsky C. 1971. The detection of chemical mutagens with enteric bacteria. In: Hollander A, ed. Chemical mutagens: Principles, and methods for their detection. Vol. 1. New York: Plenum Press, 267–282.
*Amir D. 1973. The sites of the spermicidal action of ethylene dibromide in bulls. J Reprod Fertil 35:519–525.4760150
*Amir D. 1975. Individual and age differences in the spermicidal effect of ethylene dibromide in bulls. J Reprod Fertil 44:561–565.1102680
Amir D. 1984. The spermicidal effect of ethylene dibromide in bulls and rams: A comparative study. Congressional Proceedings - 10th International Congress on Animal Reproduction and Artificial Insemination 2:33–34.
*Amir D, Ben-David E. 1973. The pattern of structural changes induced in bull spermatozoa by oral or injected ethylene dibromide (EDB). Ann Biol Anim Bioch Biophys 13:165–170.
*Amir D, Lavon U. 1976. Changes in total nitrogen, lipoproteins and amino acids in epididymal and ejaculated spermatozoa of bulls treated orally with ethylene dibromide. J Reprod Fertil 47:73–76.775080
*Amir D, Volcani R. 1965. Effect of dietary ethylene dibromide on bull semen. Nature 206:99–100.14334367
Amir D, Volcani R. 1967. The effect of dietary ethylene dibromide (EDB) on the testes of bulls: A preliminary report. Fertil Steril 18:144–148.6066821
*Amir D, Esnault C, Nicolle JC, 1977. DNA and protein changes in the spermatozoa of bulls treated orally with ethylene dibromide. J Reprod Fertil 51:453–456.338893
*Amir D, Gledhill BL, Garner DL, 1983. Spermiogenic, epididymal, and spermatozoal damage induced by a peritesticular injection of ethylene dibromide to rams. Anim Reprod Sci 6:35–50.
Amir D, Nicolle JC, Courot M. 1979. Changes induced in bull spermatids and testicular spermatozoa by a single peritesticular injection of ethylene dibromide. Int J Androl 2:162–170.
Amuh IRA. 1975. Persistence of ethylene dibromide residues in fumigated maize. Ghana J Sci 15:59–63.
*Anders MW, Livesey JC. 1980. Metabolism of 1,2-dihaloethanes. In: Ames B, Infante P, Reitz R, eds. Ethylene dichloride: A potential health risk. Banbury Report 5. Cold Spring Harbor Laboratory 331–341.
*Anderson RA, Peplinski AJ, Storey CL, 1985. Distribution of ethylene dibromide residues in whole corn and milled corn products. Cereal Chem 62:198–200.
Anonymous. 1980. Carcinogenesis bioassay of 1,2-dibromoethane. Vet Hum Toxicol 22:101–103.
Anonymous. 1982. Ethylene dibromide (EDB) revised. Vet Hum Toxicol 24:175–176.
Anonymous. 1987. Analytical technique reveals pesticide hazards. Agric Eng 68:18.
ANSI. 1970. American national standard acceptable concentrations of ethylene dibromide (1,2-dibromoethane). New York, NY: American National Standards Institute, Inc. ANSI 237.31-1970, 5–8.
*Aragno M, Tamagno E, Danni O, 1996. In vivo potentiation of 1,2-dibromoethane hepatotoxicity by ethanol through inactivation of glutathione-s-transferase. Chem Biol Interact 99(1–3):277–288.8620575
Arfellini G, Bartoli S, Colacci A, 1984. In vivo and in vitro binding of 1,2-dibromoethane and 1,2-dichloroethane to macromolecules in rat and mouse organs. J Cancer Res Clin Oncol 108:204–213.6206071
Armstrong D, Kutob R, Sipes I. 1985. Deuterium isotope effect on the expiration and tissue distribution of 1,2-dibromoethane [Abstract]. Toxicologist 5:174.
*ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry. Fed Regist 54(174):37618–37634.
*ATSDR. 2017. 1,2-Dibromoethane. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry, Centers for Disease Control and Prevention. http://www.atsdr.cdc.gov/SPL/resources/index.html. October 6, 2017.
*Bakale G, McCreary RD. 1992. Response of the k_e_ test to NCI/NTP-screened chemicals. II. Genotoxic carcinogens and non-genotoxic non-carcinogens. Carcinogenesis 13(8):1437–1445.1499095
*Ballering LA, Nivard MJ, Vogel EW. 1993. Characterization of the genotoxic action of three structurally related 1,2-dihaloalkanes in Drosophila melanogaster. Mutat Res 285(2):209–217.7678893
*Ballering LA, Vogel EW, Vrieling H, 1998. Strand-specific mutation induction by 1,2-dibromomethane at the hypoxanthine-guanine phosphoribosyltransferase locus of Chinese hamster ovary cells. Mutagenesis 13(1):61–65.9491396
*Banerjee S, Van Durren BL. 1979. Binding of carcinogenic halogenated hydrocarbons to cell macromolecules. J Natl Cancer Inst 63:707–711.381753
*Barber ED, Donish WH, Mueller KR. 1981. A procedure for the quantitative measurement of the mutagenicity of volatile liquids in the Ames Salmonella/microsome assay. Mutat Res 90:31–48.7029269
*Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486.3222488
*Barnett LB, Lovell DP, Felton CF, 1992. Ethylene dibromide: Negative results with the mouse dominant lethal assay and the electrophoretic specific-locus test. Mutat Res 282(2):127–133.1377351
Basile M. 1981. [Bromine residues in strawberries produced on soil fumigated with ethylene dibromide (EDB)]. Inf Tore Fitopatol 29:11–14. (Italian)
*Benet LZ, Sheiner LB. 1985. Pharmacokinetics: The dynamics of drugs absorption, distribution, and elimination. In: 7th ed. Goodman’s and Gilman’s: The pharmaceutical basis of therapeutics. New York, NY: MacMillan Publishing Company.
*Bentley KS, Working PK. 1988. Activity of germ-cell mutagens and nonmutagens in the rat spermatocyte UDS assay. Mutat Res 203:135–142.3352642
Berck B. 1962. Polarographic determination of methyl bromide, ethyl dibromide, acrylonitrile, chloropicrin, and carbon tetrachloride in air. J Agric Food Chem 10:158–162.
Berck B. 1974. Fumigant residues of carbon tetrachloride, ethylene dichloride, and ethylene dibromide in wheat, flour, bran, middlings, and bread. J Agric Food Chem 22:977–984.4430809
*Berkow R, ed. 1987. The Merck manual of diagnosis and therapy. 15th ed. Rahway, NJ: Merck, Sharpe & Dohme Research Laboratories.
*Bielorai R, Alumot E. 1965. Determination of ethylene dibromide in fumigated feeds and foods by gas-liquid chromatography. J Sci Food Agric 16:594–596.5841075
*Bielorai R, Alumot E. 1966. Determination of residues of a fumigant mixture in cereal grain by electron-capture gas chromatography. J Agric Food Chem 14:622–625.
Bignami M, Cardamone, G, Comba P, 1977. Relationship between chemical structure and mutagenic activity in some pesticides: The use of Salmonella typhimurium and Aspergillus nidulans. Mutat Res 46:243–244.
*Bjorge C, Brunborg G, Wiger R, 1996. A comparative study of chemically induced DNA damage in isolated human and rat testicular cells. Reprod Toxicol 10(6):509–519.8946565
*Bogen KT. 1994. Applicability of alternative models of revertant variance to Ames-test data for 121 mutagenic carcinogens. Mutat Res 322(4):265–273.7523920
*Bolt HM, Laib RJ, Peter H, 1986. DNA adducts of halogenated hydrocarbons. J Cancer Res Clin Oncol 112:92–96.3771627
*Botti B, Bini A, Calligaro A, 1986. Decrease of hepatic mitochondrial glutathione and mitochondrial injury induced by 1,2-dibromoethane in the rat in vivo: Effect of diethylmaleate pretreatment. Toxicol Appl Pharmacol 83:494–505.3518155
*Botti B, Franceschini V, Tomasi A, 1989. Mechanistic aspects of 1,2-dibromoethane-induced mitochondrial GSH depletion in vitro. Adv Biosci 76:99–105.
*Botti B, Moslen MT, Trieff NM, 1982. Transient decrease of liver cytosolic glutathione S-transferase activity in rats given 1,2-dibromoethane or CC14. Chem Biol Interact 42:259–270.6758965
*Bouwer EJ, McCarty PL. 1983. Transformations of halogenated organic compounds under dinitrification conditions. Appl Environ Microbial 45:1295–1299.
*Brandt I, Brittebo EB, Kowalski B, 1987. Tissue binding of 1,2-dibromoethane in the Cynomolgus monkey (Macaca fascicularis). Carcinogenesis 8:1359–1361.3304693
Brem H, Coward JE, Rozenkrantz HS. 1974b. 1,2-Dibromoethane: Effect on the metabolism and ultrastructure of Escherichia coli. Biochem Pharmacol 23:2345–2347.4605455
*Brem H, Stein AB, Rosenkranz HS. 1974a. The mutagenicity and DNA-modifying effect of haloalkanes. Cancer Res 34:2576–2579.4607208
Bridges RG. 1956. The fate of labelled insecticide residues in food products. V. The nature and significance of ethylene dibromide residues in fumigated wheat. J Sci Food Agric 7:305–313.
Brimer PA, Tan EL, Hsie AW. 1981. Effect of metabolic activation on the mutagenicity and cytotoxicity of ethylene dibromide in the Chinese hamster ovary hypoxanthine guanine phosphoribosyl transferase [Abstract]. Environ Mutagen 3:317–318.
*Brimer PA, Tan EL, Hsie AW. 1982. Effect of metabolic activation on the mutagenicity and cytotoxicity of ethylene dibromide in the CHO/HGPRT system. Mutat Res 95:377–388.6750385
*Brittebo EB. 1997. Metabolism-dependent activation and toxicity of chemicals in nasal glands. Mutat Res 380(1–2):61–75.9385390
*Broda C, Nachtomi E, Alumot (Olomucki) E. 1976. Differences in liver morphology between rats and chicks treated with ethylene dibromide. Gen Pharmacol 7:345–348.789175
*Brodzinsky R, Singh HB. 1983. Volatile organic chemicals in the atmosphere: An assessment of available data. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Research and Development, Environmental Sciences Research Laboratory. EPA600383027a. PB83195503.
*Bronstein AC, Currance PL. 1988. Emergency care for hazardous materials exposure. St. Louis, MO: Mosby Company, 143–144.
*Buijs W, Van der Gen A, Mohn GR, 1984. The direct mutagenic activity of alpha, omega-dihalogenoalkanes in Salmonella typhimurium. Strong correlations between chemical properties and mutagenic activity. Mutat Res 141:11–14.6384769
*Buselmaier W, Roehrborn G, Propping P. 1972. [Mutagenicity investigations with pesticides in host-mediated assay and dominant lethal test in mice]. Biol Zbl 91:311–325.
*Buselmaier W, Roehrborn G, Propping P. 1976. Comparative investigations on the mutagenicity of pesticides in mammalian test systems. Mutat Res 21:25–26.
*Cairns T, Siegmund EG, Doose GM, 1984. Confirmation of ethylene dibromide in fruits and grains by mass spectrometry. Anal Chem 56:2138–2141.6391272
*Calafat AM, Barr DB, Pirkle JL, 1999. Reference range concentrations of N-acetyl-S-(2-hydroxyethyl)-L-cysteine, a common metabolite of several volatile organic compounds, in the urine of adults in the United States. J Expo Anal Environ Epidemiol 9(4):336–342.10489158
Call F. 1957. The mechanism of sorption of ethylene dibromide on moist soils. J Sci Food Agric 8:630–639.
Capewell S. 1987. Patients presenting with lung cancer in south east Scotland. Thorax 42:853–857.2827337
Castro CE. 1988. Rebuttal on photohydrolysis of ethylene dibromide. J Agric Food Chem 36:873–874.
Castro CE, Belser NO. 1985. Photohydrolysis of ethylene dibromide. J Agric Food Chem 33:536–538.
*CDC. 2017. Fourth national report on human exposure to environmental chemicals. Updated tables, January 2017, Volume one. Atlanta, GA: Centers for Disease Control and Prevention, Department of Health and Human Services. https://www.cdc.gov/biomonitoring/pdf/FourthReport_UpdatedTables_Volume1_Jan2017.pdf. February 23, 2017.
CESARS. 1989. Chemical Evaluation Search RetrievalSsystem. Chemical Information System.
*Channarayappa, Ong T, Nath J. 1992. Cytogenetic effects of vincristine sulfate and ethylene dibromide in human peripheral lymphocytes: Micronucleus analysis. Environ Mol Mutagen 20(2):117–126.1505528
Cheeseman KH, Albano EF, Tomasi A, 1985. Biochemical studies on the metabolic activation of halogenated alkanes. Environ Health Perspect 64:85–101.3007102
*Chiarpotto E, Biasi F, Aragno M, 1995b. Ethanol-induced potentiation of rat hepatocyte damage due to 1,2-dibromoethane. Alcohol and Alcoholism (Oxford, Oxfordshire) 30(1):37–45.7748274
*Chiarpotto E, Biasi F, Scavazza A, 1995a. Acetaldehyde involvement in ethanol-induced potentiation of rat hepatocyte damage due to the carcinogen 1,2-dibromoethane. Alcohol and Alcoholism (Oxford, Oxfordshire) 30(6):721–728.8679012
*Cho SH, Guengerich FP. 2013. In vivo roles of conjugation with glutathione and O^6^-alkylguanine DNA-alkyltransferase in the mutagenicity of the bis-electrophiles 1,2-dibromoethane and 1,2,3,4-diepoxybutane in mice. Chem Res Toxicol 26(11):1765–1774. 10.1021/tx4003534.24191644
*Clark AI, McIntyre AE, Lester JN, 1982. Evaluation of a Tenax GC sampling procedure for collection and analysis of vehicle-related aromatic and halogenated hydrocarbons in ambient air. J Chromatogr 252:147–157.
Clark AI, McIntyre AE, Perry R, 1984. Monitoring and assessment of ambient atmospheric concentrations of aromatic and halogenated hydrocarbons at urban, rural, and motorway locations. Environ Pollut (Series B) 7:141–158.
*Class T, Ballschmiter K. 1986. Chemistry of organic traces in air. V. Determination of halogenated C1-C2-hydrocarbons in clean marine air and ambient continental air and rain by high resolution gas chromatography using different stationary phases. Fresenius J Anal Chem 325:107.
*Class TH, Ballschmiter K. 1988. Chemistry of organic traces in air. VIII. Sources and distribution of bromo and bromochloromethanes in marine air and surface water of the Atlantic Ocean. J Atmos Chem 6:35–46.
*Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Clive D. 1977. A linear relationship between tumorigenic potency in vivo and mutagenic potency at the heterozygous thymidine kinase (TK+/−) locus of L5178Y mouse lymphoma cell coupled with mammalian metabolism. Dev Toxicol Environ Sci 2:241–247.
*Clive D, Johnson KO, Spector JFS, 1979. Validation and characterization of the L5178Y/TK+/− mouse lymphoma mutagen assay system. Mutat Res 59:61–108.372791
Clive D, McCuen R, Spector JFS, 1983. Specific gene mutations in L5178Y cells in culture: A report of the U.S. Environmental Protection Agency Gene-Tox Program. Mutat Res 115:225–251.
Clower M, McCarthy JP, Carson LJ. 1986. Comparison of methodology for determination of ethylene dibromide in grains and grain-based foods. J Assoc Off Anal Chem 69:87–90.3512515
*Clower M, McCarthy JP, Rains DM. 1985. Effect of cooking on levels of ethylene dibromide residues in rice. J Assoc Anal Chem 68:710–711.
CLPSD. 1988. CLP Statistical Database. Viar & Company. August 10, 1988.
*Cmarik JL, Inskeep PB, Meredith MJ, 1990. Selectivity of rat and human glutathione S-transferases in activation of ethylene dibromide by glutathione conjugation and DNA binding and induction of unscheduled DNA synthesis in human hepatocytes. Cancer Res 50(9):2747–2752.2328501
Colacci A, Mazzullo M, Arfellini G, 1985. In vitro microsome- and cytosol-mediated binding of 1,2-dichloroethane and 1,2-dibromoethane with DNA. Cell Biol Toxicol 1:45–55.3917125
*Colgan ST, Krull IS, Dorschel C, 1986. Derivatization of ethylene dibromide with silica-supported silver picrate for improved high-performance liquid chromatographic detection. Anal Chem 58:2366–2372.3024524
*Collins M, Barker NJ. 1983. Direct monitoring of ambient air for ethylene oxide and ethylene dibromide. Am Lab 15:72, 74–76, 78–81.
Cone MV, Ferguson M, Powers CD, 1986a. National body-burden database chemicals identified in human biological media 1984. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances, Exposure Evaluation Division. EPA560584003, Vol. 7-Pt.-1.
Cone MV, Ferguson M, Powers CD, 1986b. National body-burden database chemicals identified in human biological media 1984. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances, Exposure Evaluation Division. EPA560584003, Vol. 7-Pt.-2.
Cone MV, Ferguson M, Powers CD, 1986c. National body-burden database chemicals identified in human biological media 1984. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances, Exposure Evaluation Division. EPA560584003, Vol. 7-Pt.-3.
*Coni P, Pichiri-Coni G, Ledda-Columbano GM, 1992. Stimulation of DNA synthesis by rat plasma following in vivo treatment with three liver mitogens. Cancer Lett 61(3):233–238.1531446
Cordle MK. 1988. USDA regulation of residues in meat and poultry products. J Anim Sci 66:413–433.3372385
Costa AK, Trudell JR. 1988. Toxicity of 1,2-dibromoethane in primary hepatocyte monolayer cultures: Lack of dependence on oxygen concentration. Toxicol Appl Pharmacol 95:241–247.3138787
*Crespi CL, Seixas GM, Turner TR, 1985. Mutagenicity of 1,2-dichloroethane and 1,2-dibromoethane in two human lymphoblastoid cell lines. Mutat Res 142:133–140.3883141
Crider WL, Slater RW Jr. 1969. Flame-luminescence intensification and quenching detector (FLIQD) in gas chromatography. Anal Chem 41:531–533.
Cumming RB, Walton MF. 1973. Modification of the acute toxicity of mutagenic and carcinogenic chemicals in the mouse by prefeeding with antioxidants. Food Cosmet Toxicol 11:547–553.4357196
Daft JL. 1983. Gas chromatographic determination of fumigant residues in stored grains, using isooctane partitioning and dual column packings. J Assoc Off Anal Chem 66:228–233.6853407
Daft JL. 1987. Determining multifumigants in whole grains and legumes, milled and low-fat grain products, spices, citrus fruit, and beverages. J Assoc Off Anal Chem 70:734–739.3624185
*Daft JL. 1988. Rapid determination of fumigant and industrial chemical residues in food. J Assoc Off Anal Chem 71:748–760.3417594
*Daft JL. 1989. Determination of fumigants and related chemicals in fatty and non-fatty foods. J Agric Food Chem 37:560–564.
*Danni O, Aragno M, Ugazio G. 1988. In vivo studies on halogen compound interactions. I. Effects of carbon tetrachloride plus 1,2-dibromoethane on liver necrosis. Res Commun Chem Pathol Pharmacol 61:377–390.3055109
*Danni O, Chiarpotto E, Aragno M, 1991. Lipid peroxidation and irreversible cell damage: Synergism between carbon tetrachloride and 1,2-dibromoethane in isolated rat hepatocytes. Toxicol Appl Pharmacol 110(2):216–222.1891769
Decarlo VJ. 1979. Studies on brominated chemicals in the environment. Ann NY Acad Sci 320:678–681.287406
Deichmann WB, Gerarde HW, eds. 1969. Toxicology of drugs and chemicals. 4^th^ ed. New York: Academic Press 257.
*DeLeve LD. 1997. Effect of decreased glutathione levels in hereditary glutathione synthetase deficiency on dibromoethane-induced genotoxicity in human fibroblasts. Mutat Res 389(2–3):291–297.9093395
*DiRenzo AB, Gandolfi AJ, Sipes IG. 1982. Microsomal bioactivation and covalent binding of aliphatic halides to DNA. Toxicol Lett 11:243–252.7101318
*Dobbins JG. 1987. Regulation and the use of “negative” results from human reproductive studies: The case of ethylene dibromide. Am J Ind Med 12:33–45.3303922
*DOE. 2016a. Protective Action Criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29 for Chemicals of Concern - May 2016. Oak Ridge, TN: U.S. Department of Energy. https://energy.gov/ehss/protective-action-criteria-pac-aegls-erpgs-teels-rev-29-chemicals-concern-may-2016. March 2, 2017.
*DOE. 2016b. Table 3: Protective Action Criteria (PAC) Rev. 29 based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. May 2016. Oak Ridge, TN: U.S. Department of Energy. https://sp.eota.energy.gov/pac/teel/Revision_29_Table3.pdf. February 28, 2017.
DOT. 1980. U.S. Department of Transportation. Code of Federal Regulations. 49 CFR 172.102.
*Dreisbach RH, Robertson WO. 1987. Handbook of poisoning: Prevention, diagnosis and treatment. Norwalk, CT: Appleton & Lange, 148–165.
Dumas T. 1962. Determination of 1,2-dibromoethane in air and as residue in fruits. J Agric Food Chem 10:476–477.
*Dumas T, Bond EJ. 1982. Microdetermination of ethylene dibromide in air by gas chromatography. J Assoc Off Anal Chem 65:1379–1381.
Dunkel VC, Zeiger E, Brusick D, 1985. Reproducibility of microbial mutagenicity assays. II. Testing of carcinogen and noncarcinogens in Salmonella typhimurium and Escherichia coli. Environ Mutagen 7(Suppl 5):1–248.
*ECHC. 2013. Screening assessment report. Ethane, 1,2-dibromo-(1,2-Dibromoethane). Chemical Abstracts Service Registry Number 106-93-4. June 2013. Environment Canada Health Canada.
*Edwards K, Jackson H, Jones Ar. 1970. Studies with alkylating esters-II: A chemical interpretation through metabolic studies of the antifertility effects of ethylene dimethanesulphonate and ethylene dibromide. Biochem Pharmacol 19:1783–1789.5513958
ElJack A, Hrudka F. 1978. Morphogenesis of the acrosomic defects in the ram induced experimentally by ethylene dibromide [Abstract]. Anat Histol Embryol 7:350.
ElJack AH, Hrudka F. 1979a. Pattern and dynamics of teratospermia induced in rams by parenteral treatment with ethylene dibromide. J Ultrastruct Res 67:124–134.381682
ElJack AH, Hrudka F. 1979b. Spermatogenesis upset by 1,2-dibromoethane. Food Cosmet Toxicol 18:743–744.
*Ellenhorn MJ, Barceloux DG. 1988. Medical toxicology. New York, NY: Elsevier, 974–976.
*Ellingham TJ, Christensen A, Maddock MB. 1986. In vitro induction of sister chromatid exchanges and chromosomal aberrations in peripheral lymphocytes of the oyster toadfish and American eel. Environ Mutagen 8:555–569.3089772
Elliott BM, Ashby J. 1980. Ethylene dibromide and disulfiram: Studies in vivo and in vitro on the mechanism of the observed synergistic carcinogenic response. Carcinogenesis 1:1049–1058.11272109
*Entz RC, Hollifield HC. 1982. Headspace gas chromatographic analysis of foods for volatile halocarbons. J Agric Food Chem 30:84–88.
*EPA. 1976. The developmental toxicity of ethylene dibromide inhaled by rats and mice during organogenesis. Washington, DC: U.S. Environmental Protection Agency. EPA560676018. PB256659. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=91012GTI.txt. November 21, 2017.
EPA. 1977. U.S. Environmental Protection Agency. Fed Regist 42:63134–63148.
*EPA. 1978. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 116.4.
EPA. 1981a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.397.
EPA. 1981b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.32.
*EPA. 1983. Ethylene dibromide (EDB). Washington, DC: U.S. Environmental Protection Agency, Office of Pesticide Programs. Position Dot #4.
EPA. 1984a. Health and environmental effects profile for 1,2-dibromoethane. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Criteria and Assessment Office. EPA600X84173. PB88131107.
EPA. 1984b. U.S. Environmental Protection Agency. Fed Regist 49:4452–4457.
EPA. 1984c. U.S. Environmental Protection Agency. Fed Regist 49:17147–17150.
*EPA. 1985. Drinking water criteria document for ethylene dibromide (EDB) (Draft). Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Criteria and Assessment Office. EPA600X84181. PB86118247.
*EPA. 1986. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 117.3.
*EPA. 1987a. Health effects assessment for ethylene dibromide. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Criteria and Assessment Office. EPA600888037. PB88180245.
*EPA. 1987b. Drinking water criteria document for ethylene dibromide (EDB). Final. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Criteria and Assessment Office. PB89192181.
EPA. 1987c. National primary drinking water regulations; synthetic organic chemicals; monitoring for unregulated contaminants. Fed Regist 52:25690–25717.
EPA. 1987d. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.40.
EPA. 1987e. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 264, Appendix IX.
EPA. 1987f. U.S. Environmental Protection Agency. Fed Regist 52:21152.
EPA. 1988a. U.S. Environmental Protection Agency. Fed Regist 53:13382.
EPA. 1988b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261, Appendix VIII.
EPA. 1989a. Interim methods for development of inhalation references doses. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. EPA600888066F.
EPA. 1989b. Recognition and management of pesticide poisonings. Washington, DC: U.S. Environmental Protection Agency. EPA540988001.
EPA. 1989c. Final draft of the drinking water criteria document for ethylene dibromide. Washington, DC: U.S. Environmental Protection Agency, Office of Drinking Water.
*EPA. 2004. Toxicological review of 1,2-dibromoethane. In support of summary information on the Integrated Risk Information System (IRIS). Washington, DC: U.S. Environmental Protection Agency. EPA635R04067.
*EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency, Office of Environmental Information. EPA260B05001.
*EPA. 2009. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency, Office of Ground Water and Drinking Water. EPA816F090004. https://www.epa.gov/sites/production/files/2016-06/documents/npwdr_complete_table.pdf. September 7, 2017.
*EPA. 2012. Drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency, Office of Water. EPA822S12001. https://www.epa.gov/sites/production/files/2015-09/documents/dwstandards2012.pdf. April 25, 2013.
*EPA. 2016. Acute Exposure Guideline Levels (AEGLs) values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2016-03/documents/compiled_aegl_update_.pdf. September 8, 2017.
*Epstein SS, Arnold E, Andrea J, 1972. Detection of chemical mutagens by the dominant lethal assay in the mouse. Toxicol Appl Pharmacol 23:288–325.5074577
*Erickson MD, Pellizzari ED. 1978. Analysis of organic air pollutants in the Kanawha Valley, WV, and the Shenandoah Valley, VA. Philadelphia, PA: U.S. Environmental Protection Agency, Region III. EPA903978007. PB286141.
Erickson SJ, Hawkins CE. 1980. Effects of halogenated organic compounds on photosynthesis in estuarine phytoplankton. Bull Environ Contam Toxicol 24:910–915.7397428
*Ewing BB, Chian ESK, Cook JC, 1977. Monitoring to detect previously unrecognized pollutants in surface waters. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances. EPA560677015.
Fabricant JD, Chalmers JH Jr. 1980. Evidence of the mutagenicity of ethylene dichloride and structurally related compounds. In: Ames B, Infante P, Reitz R, eds. Ethylene dichloride: A potential health risk. Banbury Report No. 5. Cold Spring Harbor Laboratory 309–322.
Fahrig R. 1974. Comparative mutagenicity studies with pesticides. IARC Sci Pub 10:161–181.
*Fanini D, Legator MS, Adams PM. 1984. Effects of paternal ethylene dibromide exposure on F_l_ generation behavior in the rat. Mutat Res 139:133–138.6366538
FDA. 1975a. U.S. Food and Drug Administration, Human Health Services. Code of Federal Regulations. 21 CFR 193.225.
FDA. 1975b. U.S. Food and Drug Administration, Human Health Services. Code of Federal Regulations. 21 CFR 193.230.
*FDA. 2013. Everything added to food in the United States (EAFUS). Washington, DC: U.S. Food and Drug Administration. http://www.accessdata.fda.gov/scripts/fcn/fcnnavigation.cfm?rpt=eafuslisting. January 8, 2014.
*FDA. 2017. Subpart B - Requirements for specific standardized beverages. Bottled water. U.S. Food and Drug Administration. Code of Federal Regulations 21 CFR 165.110. https://www.gpo.gov/fdsys/pkg/CFR-2017-title21-vol2/pdf/CFR-2017-title21-vol2-sec165-110.pdf. September 7, 2017.
*Ferreri AM, Rocchi P, Capucci A, 1983. Induction of diphtheria toxin-resistant mutants in human cells by halogenated compounds. J Cancer Res Clin Oncol 105:111–112.6339513
*Fishbein L. 1979. Potential halogenated industrial carcinogenic and mutagenic chemicals: III. Alkane halides, alkanols and ethers. Sci Total Environ 11:223–257.155878
*Fishbein L. 1980. Production, uses, and environmental fate of ethylene dichloride and ethylene dibromide. In: Ames B, Infante P, Reitz R, eds. Ethylene dichloride: A potential health risk? Banbury Report 5. Cold Spring Harbor, NY: Cold Spring Laboratory 227–238.
Fisher-Fischbein J. 1987. New frontiers in male reproductive toxicology? Am J Ind Med 11:611–614.3605100
Foster PL, Wilkinson WG, Miller JK, 1988. An analysis of the mutagenicity of 1,2-dibromoethane to Escherichia coli: Influence of DNA repair activities and metabolic pathways. Mutat Res 194:171–183.3054522
*Foureman P, Mason JM, Valencia R, 1994. Chemical mutagenesis testing in Drosophila: X. Results of 70 coded chemicals tested for the National Toxicology Program. Environ Mol Mutagen 23(3):208–227.8162896
FSTRAC. 1988. Chemical Communication Subcommittee Federal-State Toxicology and Regulatory Alliance Committee. Summary of state and federal drinking water standards and guidelines, Washington, DC.
Geddes AD. 1982. Sister-chromatid exchange (SCE) induction in human lymphocytes in vitro by 1,2-dibromoethane with and without metabolic activation. Mutat Res 97:188–189.
*Ghanayem BI, Maronpot RR, Matthews HB. 1986. Association of chemically induced forestomach cell proliferation and carcinogenesis. Cancer Lett 32:271–278.3768853
*Girish GK, Kumar A. 1975. Studies on the residues in wheat and wheat products fumigated with ethylene dibromide. Bull Grain Technol 13:131–135.
Going J, Long S. 1975. Sampling and analysis of selected toxic substances. Task II-ethylene dibromide. Final Report. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances. EPA560675001.
Gold LS, Slone TH, Berstein L. 1989. Summary of carcinogenic potency and positivity for 492 rodent carcinogens in the carcinogenic potency database. Environ Health Perspect 79:259–272.2707207
*Goyal R, Tardif R, Brodeur J. 1989. Influence of a cysteine prodrug, L-2-oxothiazolidine-4-carboxylic acid, on the urinary elimination of mercapturic acids of ethylene oxide, dibromoethane, and acrylonitrile: A dose-effect study. Can J Physiol Pharmacol 67:207–212.2663124
Graf U, Wurgler FE, Katz AL, 1984. Somatic mutation and recombination test in Drosophila melanogaster. Environ Mutagen 6:153–188.6423380
Grant WM. 1986. Toxicology of the eye. 3rd ed. Springfield, IL: Charles C. Thomas, 316.
*Graves RJ, Trueman P, Jones S, 1996. DNA sequence analysis of methylene chloride-induced HPRT mutations in Chinese hamster ovary cells: Comparison with the mutation spectrum obtained for 1,2-dibromoethane and formaldehyde. Mutagenesis 11(3):229–233.8671744
Grimmer G, Schmidt W. 1986. Model experiments on the phytotoxicity of halogenated hydrocarbons. Angew Chem Int Ed Engl 25:808–809.
*Guengerich FP. 1994. Mechanisms of formation of DNA adducts from ethylene dihalides, vinyl halides, and arylamines. Drug Metab Rev 26(1–2):47–66. 10.3109/03602539409029784.8082581
*Guengerich FP. 2005. Principles of covalent binding of reactive metabolites and examples of activation of bis-electrophiles by conjugation. Arch Biochem Biophys 433(2):369–378. 10.1016/j.abb.2004.07.035.15581593
*Guengerich FP, Kim DH, Iwasaki M. 1991. Role of human cytochrome P-450 IIE1 in the oxidation of many low molecular weight cancer suspects. Chem Res Toxicol 4(2):168–179.1664256
*Guengerich FP, Thier R, Persmark M, 1995. Conjugation of carcinogens by theta class glutathione S-transferases: Mechanisms and relevance to variations in human risk. Pharmacogenetics 5:S103–S107.7581478
Guengerich FP, Peterson LA, Cmarik JL, 1987. Activation of dihaloalkanes by glutathione conjugation and formation of DNA adducts. Environ Health Perspect 76:15–18.3329096
Gupta RC, Dave SK, Shah MP, 1980. A monitoring study of pesticide applicators employed by pest control agencies. Prog Ecol 5/7:297–304.
Haddad LM, Winchester JF. 1990. Clinical management of poisoning and drug overdose. Philadelphia, PA: W.B. Saunders Co., 1242–1243.
Hardin BD, Bond GP, Sikov MR, 1981. Testing of selected workplace chemicals for teratogenic potential. Scand J Work Environ Health 7(Suppl 4):66–75.7330632
Harkov R, Kebbekus B, Bozzelli JW, 1983. Measurement of selected volatile organic compounds at three locations in New Jersey during the summer season. J Air Pollut Control Assoc 33:1177–1183.
Harkov R, Kebbekus B, Bozzelli JW, 1984. Comparison of selected volatile organic compounds during the summer and winter at urban sites in New Jersey. Sci Total Environ 38:259–274.
Hauser TR, Bromber SM. 1982. EPA’s monitoring program at Love Canal 1980. Environ Monit Assess 2:249–271.24264296
*Heikes DL, Hopper ML. 1986. Purge and trap method for determination of fumigants in whole grains, milled grain products, and intermediate grain-based foods. J Assoc Off Anal Chem 69:990–998.3542956
*Heinrichs WL. 1983. Reproductive hazards of the workplace and the home. Clin Obstet Gynecol 26:429–436.6851291
*Hellman B, Brandt I. 1986. Effects of carcinogenic halogenated aliphatic hydrocarbons on [3H]thymidine incorporation into various organs of the mouse: A comparison between 1,2-dibromoethane and 1,2-dichloroethane. Mutat Res 163:193–199.3531831
*Hemminki K, Falck K, Vainio H. 1980. Comparison of alkylation rates and mutagenicity of directly acting industrial and laboratory chemicals. Arch Toxicol 46:277–285.7236006
Herring CO, Adams JA, Wilson BA, 1988. Dose-response studies using ethylene dibromide (EDB) in Hydra olizactis. Bull Environ Contam Toxicol 40:35–40.3278760
*Hill DL, Tzu-Wen S, Johnson TP, 1978. Macromolecular binding and metabolism of the carcinogen 1,2-dibromoethane. Cancer Res 38:2438–2442.27300
Hirsch. 1988. Ethyl bromide and ethyl bromide narcosis. Therapeutische Monatshefte 2:556–557.
*Hissink AM, Wormhoudt LW, Sherratt PJ, 2000. A physiologically-based pharmacokinetic(PB-PK) model for ethylene dibromide: Relevance of extrahepatic metabolism. Food Chem Toxicol 38(8):707–716.10908818
*Hoppin JA, Umbach DM, London SJ, 2009. Pesticide use and adult-onset asthma among male farmers in the Agricultural Health Study. Eur Respir J 34(6):1296–1303. 10.1183/09031936.00005509.19541724
*HSDB. 1989. Hazardous Substances Data Bank. Bethesda, MD: National Library of Medicine, National Toxicology Informational Program.
*Hsu LL, Adams PM, Fanini D, 1985. Ethylene dibromide: Effects of paternal exposure on the eurotransmitter enzymes in the developing brain of F1 progeny. Mutat Res 147:197–203.3894950
Huff JE. 1983. 1,2-Dibromoethane (ethylene dibromide). Environ Health Perspect 47:359–363.6337831
Huff JE, McConnell EE, Haseman JK, 1988. Carcinogenesis studies results of 398 experiments on 104 chemicals from the U.S. National Toxicology Program. In: Maltoni C, Selikoff IJ, eds. Annals of the New York Academy of Sciences. Living in a chemical world: Occupational and environmental significance of industrial carcinogens. Vol. 534. New York NY: New York Academy of Sciences, 1–30.
*Hughes TJ, Simmons DM, Monteith LG, 1987. Vaporization technique to measure mutagenic activity of volatile organic chemicals in the Ames/Salmonella assay. Environ Mutagen 9:421–441.3556157
*Humphreys WG, Kim DH, Cmarik JL, 1990. Comparison of the DNA-alkylating properties and mutagenic responses of a series of S-(2-haloethyl)-substituted cysteine and glutathione derivatives. Biochemistry 29(45):10342–10350.2261477
Hunder G, Schmid A. 1988. in vivo metabolism of 1,2-dibromoethane (DBE). Arch Pharmacol 337(Suppl):R18.
IARC. 1977. Ethylene dibromide. IARC monographs on the evaluation of the carcinogenic risk of chemicals to man: Some fumigants, the herbicides 2,4-D and 2,4,5-T, chlorinated dibenzodioxins and miscellaneous industrial chemicals, Vol. 15. International Agency for Research on Cancer, 195–209.
*IARC. 1987. IARC monographs on the evaluation of carcinogenic risks to humans. Lyon, France: International Agency for Research on Cancer, Supp 7.
*IARC. 1999. Ethylene dibromide (1,2-dibromoethane). IARC Monographs on the evaluation of carcinogenic risks to humans. Volume 71. Re-evaluation of some organic chemicals, hydrazine and hydrogen peroxide. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Monographs/vol71/mono71-28.pdf. October 30, 2017.
Igwe OJ, Que Hee SS, Wagner WD. 1986. Interaction between 1,2-dichloroethane and disulfiram. I. Toxicologic effects. Fundam Appl Toxicol 6:733–746.3710039
Infante PF, Tsongas TA. 1982. Mutagenic and oncogenic effects of chloromethanes, chloroethanes, and halogenated analogues of vinyl chloride. Environ Sci Res 25:301–327.
*Inskeep PG, Guengerich FP. 1984. Glutathione-mediated binding of dibromoalkanes to DNA: Specificity of rat glutathione-S-transferases and dibromoalkane structure. Carcinogenesis 5:805–808.6373044
*Inskeep PG, Koga N, Cmarid JL, 1986. Covalent binding of 1,2-dihaloalkanes to DNA and stability of the major DNA adduct, S-[2-(N7-guanyl)ethyl]glutathione. Cancer Res 46:2839–2844.2870801
*IRIS. 2004. 1,2-Dibromoethane. Integrated Risk Information System. Chemical assessment summary. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0361_summary.pdf. October 30, 2017.
Ivanetich KM, Thumser AE, A. 1987. Reversible inhibition and activation of hepatic GSH S-transferases by ethylene dibromide. Pharmacol Ther 33:85–88.3306718
Ivanetich KM, Ziman MR, Mennie REM, 1984. Inhibition of rat GSH S-transferases by ethylene dibromide. Res Commun Chem Pathol Pharmacol 45:233–242.6385169
*Izutani K, Nakata A, Shinagawa H, 1980. Forward mutation assay for screening carcinogens by alkaline phosphatase constitutive mutations in Escherichia coli K-12. Biken J 23:69–75.7006595
*Jaber HM, Mabey WR, Liu AT, 1984. Data acquisition for environmental transport and fate screening for compounds of interest to the Office of Emergency and Remedial Response. Washington, DC: U.S. Environmental Protection Agency. EPA600684011. PB84245281.
Jackson RJ, Goldman L. 1985. Pesticide residues in food. Pediatrics 76:473–474.4034312
*Jakobson I, Wahlberg JE, Holmberg B, 1982. Uptake via the blood and elimination of 10 organic solvents following epicutaneous exposure of anesthetized guinea pigs. Toxicol Appl Pharmacol 63:181–187.7089968
Johns R. 1976. Air pollution assessment of ethylene dibromide. Gov Rep Announce Index 76:131.
Jones CJ, Hudson BC, McGugan PJ, 1978. The leaching of some halogenated organic compounds from domestic waste. J Hazard Mater 2:227–233.
Jurinak JJ. 1957. The effect of clay minerals and exchangeable cations on the adsorption of ethylene dibromide vapor. Soil Science Society Proceedings 21:599–602.
Jury WA, Focht DD, Farmer WJ. 1987. Evaluation of pesticide groundwater pollution potential from standard indices of soil-chemical adsorption and biodegradation. J Environ Qual 16:422–428.
*Kado NY, Wong JM, Kuzmicky PA, 1992. Quantitative integration of the Salmonella microsuspension assay with supercritical fluid extraction of model airborne vapor-phase mutagens. Mutat Res 271(3):253–260.1378198
*Kale PG, Baum JW. 1979. Sensitivity of Drosophila melanogaster to low concentrations of gaseous mutagens: II. Chronic exposures. Mutat Res 68:59–68.114827
*Kale PG, Baum JW. 1981. Sensitivity of Drosophila melanogaster to low concentrations of gaseous mutagens: III. Dose-rate effects. Environ Mutagen 3:65–70.6790276
*Kale P, Baum JW. 1982. Genetic effects of ethylene dibromide in Drosophila melanogaster. Environ Sci Res 25:291–300.
*Kale PG, Baum JW. 1983. Sensitivity of Drosophila melanogaster to low concentrations of gaseous mutagens: IV. Mutations in embryonic spermatogonia. Mutat Res 113:135–143.6403851
*Kale P, Kale R. 1995. Induction of delayed mutations by benzene and ethylene dibromide in Drosophila. Environ Mol Mutagen 25(3):211–215.7737139
*Kaphalia BS, Ansari GA. 1992. Covalent binding of ethylene dibromide and its metabolites to albumin. Toxicol Lett 62(2–3):221–230.1412507
*Kerklaan PRM, Zoetemelk CEM, Mohn GR. 1985. Mutagenic activity of various chemicals in Salmonella strain TA100 and glutathione-deficient derivatives: On the role of glutathione in the detoxification or activation of mutagens inside bacterial cells. Biochem Pharmacol 34:2151–2156.4004932
*Kim DH, Guengerich FP. 1989. Excretion of the mercapturic acid S-[2-N7guanyl) ethyl]-N-acetylcysteine in urine following administration of ethylene dibromide to rats. Cancer Res 49:5843–5847.2790795
*Kim DH, Guengerich FP. 1990. Formation of the DNA adduct S-(2(N7-guanyl)ethyl)glutathione from ethylene dibromide: Effects of modulation of glutathione and glutathione S-transferase levels and lack of a role for sulfation. Carcinogenesis 11(3):419–424.2311185
*Kirby KW, Tremmel H, Keiser JE. 1980. Determination and metabolism of ethylene dibromide in minipigs. Bull Environ Contam Toxicol 25:774–777.
*Kluwe WM, Harrington FW, Cooper SE. 1982. Toxic effects of organohalide compounds on renal tubular cells in vivo and in vitro. J Pharmacol Exp Ther 220:597–603.7062270
*Kluwe WM, McNish R, Hook JB. 1981. Acute nephrotoxicities and hepatoctoxicities of 1,2-dibromo3-chloropropane and 1,2-dibromoethane in male and female F344 rats. Toxicol Lett 8:317–321.7029782
*Koga N, Inskeep PB, Harris TM, 1986. S-[2-(N7-Guanyl)ethyl] glutathione, the major DNA adduct formed from 1,2-dibromoethane. Biochemistry 25:2192–2198.3707941
*Kowalski B, Brittebo EB, Brandt I. 1985a. Epithelial binding of 1,2-dibromoethane in the respiratory and upper alimentary tracts of mice and rats. Cancer Res 45:2616–2625.3886135
*Kowalski B, Brittebo EB, d’Argy R, 1986. Fetal epithelial binding of 1,2-dibromoethane in mice. Carcinogenesis 7:1709–1714.3530523
*Kowalski JD, Shikiya JM, Tsou G. 1985b. Ambient sampling and analysis to halogenated hydrocarbons and benzene. Proc APCA Annu Meet 2:85–171.
Kowalski J, Tsou G, Daymon D, 1987. A method to prepared ambient concentrations of gas standards for halogenated hydrocarbons. Proc APCA Ann Meet 4:87/62.10, 13.
*Kramers PG, Mout HC, Bissumbhar B, 1991. Inhalation exposure in Drosophila mutagenesis assays: Experiments with aliphatic halogenated hydrocarbons, with emphasis on the genetic activity profile of 1,2-dichloroethane. Mutat Res 252(1):17–33.1996129
Kraybill HF. 1978. Carcinogenesis induced by trace contaminants in potable water. Bull NY Acad Med 54:413–427.
*Krill RM, Sonzogni WC. 1986. Chemical monitoring of Wisconsin’s groundwater. J Am Water Works Assoc 78:70–75.
*Krishna G, Xu J, Nath J, 1985. in vivo cytogenetic studies on mice exposed to ethylene dibromide. Mutat Res 158:81–87.3900721
*Krishnan K, Anderson ME, Clewell HJ, 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
*Kroneld R. 1985. Recovery and reproducibility in determination of volatile halocarbons in water and blood. Bull Environ Contam Toxicol 34:486–496.3986386
Lal M, Monig J, Asmus K-D. 1986. Free radical induced degradation of 1,2-dibromoethane. Generation of free Br atoms. Free Radic Res Commun 1(4):235–241.3333033
Lal M, Schoneich C, Monig J, 1988. Rate constants for the reaction of halogenated organic radicals. Int J Radiat Biol 54:773–785.2902171
*LaRegina J, Bozzelli JW, Harkov R, 1986. Volatile organic compounds at hazardous waste sites and a sanitary landfill in New Jersey: An up-to-date review of the present situation. Environ Prog 5:18–27.
*Lawrence FH, Michaels RA. 1984. Ethylene dibromide (EDB): A guide for decision makers. Envirologic Data. Portland, ME: Envirologic Data, Inc., 122.
*Ledda-Columbano GM, Columbano A, Coni P, 1987a. Liver cell proliferation induced by the mitogen ethylene dibromide, unlike compensatory cell proliferation, does not achieve initiation of rat liver carcinogenesis by diethylnitrosoamine. Cancer Lett 36:247–252.2888528
*Ledda-Columbano GM, Columbano A, Coni P, 1987b. Cell proliferation in rat kidney induced by 1,2-dibromoethane. Toxicol Lett 37:85–90.3296322
Leenhouts HP, Sijsma MJ, Cebulska-Wasilewska A, 1986. The combined effect of DBE and x-rays on the induction of somatic mutations in Tradescantia. Int J Radiat Biol Relat Stud Phys Chem Med 49:109–119.3510180
Lehning E, Polin D, Whalen T. 1986. Ethylene dibromide EDB residues in chicken tissues and eggs during and after feeding EDB-contaminated diet. Poult Sci 65(Suppl 1):77.
*Letz GA, Pond SM, Osterloh JD, 1984. Two fatalities after acute occupational exposure to ethylene dibromide. J Am Med Assoc 252:2428–2431.
Lipsett MJ, Carmelli D, Winship-Ball A, 1982. Quantitative cancer risk assessment for occupational exposure to ethylene dibromide. Govt Reports Announcements & Index (GRA&I). Cincinnati, OH: Robert A. Taft Labs. PB83184325.
*Liu H, Xu-Welliver M, Pegg AE. 2000. The role of human O^6^-alkylguanine-DNA alkyltransferase in promoting 1,2-dibromoethane-induced genotoxicity in Escherichia coli. Mutat Res 452(1):1–10.10894884
*Liu L, Hachey DL, Valadez G, 2004. Characterization of a mutagenic DNA adduct formed from 1,2-dibromoethane by O^6^-alkylguanine-DNA alkyltransferase. J Biol Chem 279(6):4250–4259. 10.1074/jbc.M311105200.14645247
*Liu L, Pegg AE, Williams KM, 2002. Paradoxical enhancement of the toxicity of 1,2-dibromoethane by O^6^-alkylguanine-DNA alkyltransferase. J Biol Chem 277(40):37920–37928. 10.1074/jbc.M205548200.12151404
*Liu L, Watanabe K, Fang Q, 2007. Effect of alterations of key active site residues in O^6^-alkylguanine-DNA alkyltransferase on its ability to modulate the genotoxicity of 1,2-dibromoethane. Chem Res Toxicol 20(1):155–163. 10.1021/tx600257g.17226938
Loague KM, Green RE, Liu CC, K., 1989. Simulation of organic chemical movement in Hawaii soils with PRZM: 1. Preliminary results for ethylene dibromide. Pacific Sci 43(1):67–95.
Loper JC. 1980. Mutagenic effects of organic compounds in drinking water. Mutat Res 76:241–268.7010128
Ma TH, Sparrow AH, Schairer LA, 1978. Effect of 1,2-dibromoethane (DBE) on meiotic chromosomes of Tradescantia. Mutat Res 58:251–258.
MacFarland RT, Gandolfi AJ, Sipes IG. 1984. Extra hepatic reduced GSH-dependent metabolism of 1,2-dibromoethane and 1,2-dibromo-3-chloropropane (DBCP) in the rat and mouse. Drug Chem Toxicol 7:213–227.6376058
Mackison FW, Stricoff RS, Partridge LJ Jr. 1978. Occupational health guidelines for ethylene dibromide. NIOSH/OSHA-Occupational health guidelines for chemical hazards. DHHS (NIOSH) Publication, 3.
Maiorino RM, Gandolfi AJ, Brendel K, 1982. Chromatographic resolution of amino acid adducts of aliphatic halides. Chem Biol Interact 38:175–188.7055850
*Malling HV. 1969. Ethylene dibromide: A potent pesticide with high mutagenic activity [Abstract]. Genetics 61:39.
Mandel HG. 1971. Pathways of drug biotransformation. Biochemical conjunctions. In: Ladu BN, Mandel HG, Way EL, eds. Fundamentals of drug metabolism and drug disposition 167–168.
*Mann AM, Darby FJ. 1985. Effects of 1,2-dibromoethane on glutathione metabolism in rat liver and kidney. Biochem Pharmacol 34:2827–2830.3896244
Maronpot RR, Shimkin MB, Witschi HP, 1986. Strain A mouse pulmonary tumor test results for chemicals previously tested in the National Cancer Institute carcinogenicity tests. J Natl Cancer Inst 76:1101–1112.3458947
*Marti LR, DeKanel J, Dougherty RC. 1984. Screening for organic contamination of groundwater: Ethylene dibromide in Georgia irrigation wells. Environ Sci Technol 18:973–974.
*McCall SN, Jurgens P, Ivanetich KM. 1983. Hepatic microsomal metabolism of the dichloroethanes. Biochem Pharmacol 32:207–213.6870950
*McCann J, Choi E, Yamasaki E, 1975. Detection of carcinogens as mutagens in the Salmonella/microsome test: Assay of 300 chemicals. Proc Natl Acad Sci 72:5135–5139.1061098
McKenry MV. 1974. The behavior of pesticides containing 1,3-dichloropropene and 1,2-dibromoethane in soils. Diss Abstr Int 34:3034B.
*McKone TE. 1987. Human exposure to volatile organic compounds in household tap water: The indoor inhalation pathway. Environ Sci Technol 21:1194–1201.
Melnikov NN. 1971. Chemistry of pesticides. In: Gunther FA, Gunther JD, eds. University of Moscow New York, Heidelberg, Berlin: Springer-Verlag, 38–39.
*Meneghini R. 1974. Repair replication of opossum lymphocyte DNA: Effect of compounds that bind to DNA. Chem Biol Interact 8:113–126.4374318
*Mersch-Sundermann V, Schneider U, Klopman G, 1994. SOS induction in Escherichia coli and Salmonella mutagenicity: A comparison using 330 compounds. Mutagenesis 9(3):205–224.7934961
*Michael LC, Pellizzari ED, Wiseman RW. 1988. Development and evaluation of a procedure for determining volatile organics in water. Environ Sci Technol 22:565–570.22195629
*Milks MM, Wilt SR, Ali I, 1982. Dibromoethane effects on the induction of γ-glutamyl-transpeptidase positive foci in rat liver. Arch Toxicol 51:27–35.
Millar JD. 1984. Occupational Safety and Health Administration proposed rule: Occupational exposure to ethylene dibromide. Cincinnati, OH: National Institute for Occupational Safety and Health. PB85164713/GAR, 62.
Minor JL, Short RD, Seifter J, 1978. Effects of ethylene dibromide inhaled by rats and mice during gestation. Toxicol Appl Pharmacol 45:347.
*Moriya M, Ohta T, Watanabe K, 1983. Further mutagenicity studies on pesticides in bacterial reversion assay systems. Mutat Res 116:185–216.6339892
*Moslen MT. 1984. Increased incidence of hepatic foci and nodules in rats given one or two doses of 1,2-dibromoethane. Toxicol Pathol 12:307–314.6398500
Moye HA, Weintraub R. 1988. Comment on “Reaction products and rates of disappearance of simple bromoalkanes, 1,2-dibromopropane, and 1,2-dibromoethane in water.” Environ Sci Technol 22:231.
*Nachtomi E. 1970. Metabolism of ethylene dibromide in the rat: The enzymic reaction with glutathione in vitro and in vivo. Biochem Pharmacol 19:2853–2860.5512693
*Nachtomi E. 1981. Role of diethyldithiocarbamate in ethylene dibromide metabolism and covalent binding. Toxicol Appl Pharmacol 57:247–253.6261417
*Nachtomi E, Alumot E. 1972. Comparison of ethylene dibromide and carbon tetrachloride toxicity in rats and chicks: Blood and liver levels; lipid peroxidation. Exp Mol Pathol 16:71–78.5060123
*Nachtomi E, Sarma DS. 1977. Repair of rat liver DNA in vivo damaged by ethylene dibromide. Biochem Pharmacol 26:1941–1945.199199
Nachtomi E, Farber E. 1978. Ethylene dibromide as a mitogen for liver. Lab Invest 38:279–283.344989
*Nachtomi E, Alumot E, Bondi A. 1965. The metabolism of ethylene dibromide (EDB) and related compounds in the rat. Israel J Chem 3:119–120.
*Nachtomi E, Alumot E, Bondi A. 1966. The metabolism of ethylene dibromide in the rat. I. Identification of detoxification products in urine. Israel J Chem 4:239–246.
Naik MN Jr. 1971. Fate of pesticides in soil. Pesticides 5:24–26.
*NAS/NRC. 1989. Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences/National Research Council. National Academy Press, 15–35.
NATICH. 1988. National Air Toxics Information Clearinghouse. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards.
*NCI. 1978. Bioassay of 1,2-dibromoethane for possible carcinogenicity. Bethesda, MD: National Cancer Institute. PB288428.
Nguyen T, Ollis DF. 1984. Complete heterogeneously photocatalyzed transformation of 1,1- and 1,2-dibromoethane to CO_2_ and HBr. J Phys Chem 88:3386–3388.
*NIOSH. 1977. Criteria for a recommended standard occupational exposure to ethylene dibromide. U.S. Department of Health, Education, and Welfare. Cincinnati, OH: U.S. Department of Health and Human Services. DHEW (NIOSH) 77–221.
NIOSH. 1978. NIOSH Current intelligence bulletin reprints; Bulletins 1 through 18. U.S. National Institute for Occupational Safety and Health. Cincinnati, OH: Surveillance Hazard Evaluations, and Field Studies, NIOSH. PB83105080.
NIOSH. 1979. NIOSH current intelligence bulletin reprints. Bulletins 19 through 30 for 1978. Bahlman LJ, ed. Rockville, MD: U.S. Department of Health, Education, and Welfare, Office of Extramural Coordination and Special Projects. DHEW (NIOSH) Publication No. 79–146.
*NIOSH. 1981. Current intelligence bulletin 37: Ethylene dibromide (EDB) (revised). Cincinnati, OH: National Institute for Occupational Safety and Health. DHHS/PUB/NIOSH-82-105. PB83101774.
*NIOSH. 1985. NIOSH pocket Guide to chemicals hazards. Washington, DC: U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health. DHHS (NIOSH) Publication No. 85–114.
*NIOSH. 1987. NIOSH manual of analytical methods. 3rd ed., 2nd Suppl. Cincinnati, OH: U.S. Department of Health and Human Services. NIOSH Publication No. 87–117.
*NIOSH. 1994. Ethylene dibromide. Immediately Dangerous to Life or Health Concentrations (IDLH). Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. https://www.cdc.gov/niosh/idlh/106934.html. October 30, 2017.
*NIOSH. 2016. Ethylene dibromide. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. https://www.cdc.gov/niosh/npg/npgd0270.html. October 30, 2017.
Nirmalakhandan NN, Speece RE. 1988. QSAR model for predicting Henry’s constant. Environ Sci Tech 22:1349–1357.
*Nitschke KD, Kociba RJ, Keyes DG, 1981. A thirteen week repeated inhalation study of ethylene dibromide in rats. Fundam Appl Toxicol 1:437–442.6764425
*Novotna B, Duverger-van Bogaert M. 1994. Role of kidney S9 in the mutagenic properties of 1,2-dibromoethane. Toxicol Lett 74(3):255–263.7871549
NRC. 1980. Ethylene dibromide(1,2-dibromoethane). Drinking Water and Health. Washington, DC: National Research Council, National Academy of Sciences, National Academy Press. 98–100.
*NTP. 1982. Carcinogenesis bioassay of 1,2-dibromoethane (CAS No. 106-93-4) in F344 rats and B6C3F1 mice (inhalation study). National Toxicology Program Technical Report Series. Research Triangle Park, NC: U.S. National Toxicology Program. PB82181710.
*NTP. 1989. Personal communication. Beth Anderson, National Toxicology Program, Research Triangle Park, NC.
*NTP. 2016. 1,2-Dibromoethane. Report on carcinogens, Fourteenth edition. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program. https://ntp.niehs.nih.gov/ntp/roc/content/profiles/dibromoethane.pdf. October 30, 2017.
*Oda Y, Yamazaki H, Thier R, 1996. A new Salmonella typhimurium NM5004 strain expressing rat glutathione S-transferase 5-5: Use in detection of genotoxicity of dihaloalkanes using an SOS/umu test system. Carcinogenesis 17(2):297–302.8625454
*Oki DS, Giambelluca TW. 1987. DBCP, EDB, and TCP contamination of groundwater in Hawaii. Groundwater 25:693–702.
Ollis DF. 1985. Contaminant degradation in water: Heterogeneous photocatalysis degrades halogenated hydrocarbon contaminants. Environ Sci Technol 19:480–484.22257346
*Olmstead EV. 1960. Pathological changes in ethylene dibromide poisoning. AMA Arch Ind Health 21(6):45–49, 525–529.
OSHA. 1974. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000.
OSHA. 1980. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.20.
OSHA. 1987. OSHA Standards. Occupational Safety and Health Administration. 29 CFR 1910.20, 85–92.
*OSHA. 2016a. Subpart D - Occupational health and environment controls. Gases, vapors, fumes, dusts, and mists. Code of Federal Regulations. Occupational Safety and Health Standards. 29 CFR 1926.55. https://www.gpo.gov/fdsys/pkg/CFR-2016-title29-vol8/pdf/CFR-2016-title29-vol8sec1926-55.pdf. March 6, 2017.
*OSHA. 2016b. Subpart Z - Toxic and hazardous substances. Air contaminants. Code of Federal Regulations. Occupational Safety and Health Standards. 29 CFR 1910.1000. https://www.gpo.gov/fdsys/pkg/CFR-2016-title29-vol6/pdf/CFR-2016-title29-vol6-sec1910-1000.pdf. March 6, 2017.
*OSHA. 2017. Subpart Z - Toxic and hazardous substances. Air contaminants. Code of Federal Regulations. Occupational Safety and Health Standards. 29 CFR 1915.1000. https://www.gpo.gov/fdsys/pkg/CFR-2017-title29-vol7/pdf/CFR-2017-title29-vol7-sec1915-1000.pdf. September 7, 2017.
Otson R. 1987. Purgeable organics in Great Lakes raw and treated water. Int J Environ Anal Chem 31:41–53.
*Ott MG, Scharnweber HC, Langner RR. 1980. Mortality experience of 161 employees exposed to ethylene dibromide in two production units. Br J Ind Med 37:163–168.7000159
*Ozawa N, Guengerich FP. 1983. Evidence for formation of an S-[2(N7-guanyl]ethyl)glutathione adduct in glutathione-mediated binding of the carcinogen 1,2-dibromoethane to DNA. Proc Natl Acad Sci USA 80:5266–5270.6577422
*Page BD, Newsome WH, MacDonald SB. 1987. Determination of several halogenated fumigants in cereal products by steam distillation and capillary gas chromatography with electron capture detection. J Assoc Off Anal Chem 70:446–450.3610956
*Page GW. 1981. Comparison of groundwater and surface water for patterns and levels of contamination by toxic substances. Environ Sci Technol 15:1475–1481.
*Parkin DM, Wahrendorf J. 1987. Directory of on-going research in cancer epidemiology. IARC Scientific Publication f/86. Lyon, France: World Health Organization, International Agency for Research on Cancer, 384.
*Parrish CF. 1983. Industrial solvents. In: Grayson M, ed. Kirk-Othmer encyclopedia of chemical technology. Vol. 23. New York, NY: John Wiley and Sons, 381.
*Patterson DG, Hampton L, Lapeza CR, 1987. High-resolution gas chromatographic/high-resolution mass spectrometric analysis of human serum on a whole-weight and lipid basis for 2,3,7,8-tetrachlorodibenzo-p-dioxin. Anal Chem 59:2000–2005.3631519
PDR. 1991. Physicians’ desk reference. 45th ed. Oradell, NJ: Medical Economics Data, 2358–2359.
*Pellizzari ED, Zweidinger RA, Erickson MD. 1978. Environmental monitoring near industrial sites: Brominated chemicals. Part I. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Toxic Substances. EPA560678002. PB286484.
Pereira MA, Stoner GD. 1985. Comparison of rat liver foci assay and strain A mouse lung tumor assay to detect carcinogens: A review. Fundam Appl Toxicol 5:688–699.3899833
*Perocco P, Prodi G. 1981. DNA damage by haloalkanes in human lymphocytes cultured in vitro. Cancer Lett 13:213–218.6457684
*Peterson LA, Harris TM, Guengerich FP. 1988. Evidence for an episulfonium ion intermediate in the formation of S-(2-N7-guanyl)ethyl)glutathione in DNA. J Am Chem Soc 110:3284–3291.
*Pflesser G. 1938. [Skin-damaging effect of ethylene dibromide, a constituent of the liquid from remote water gauges]. Archiv fuer Gewerbepathologie und Gewerbehygiene 8:591–600. (German)
*Pignatello JJ. 1986. Ethylene dibromide mineralization in soils under aerobic conditions. Appl Environ Microbial 51:588–592.
*Pignatello JJ. 1987. Microbial degradation of 1,2-dibromoethane in shallow aquifer materials. J Environ Qual 16:307–312.
*Ploemen JP, Wormhoudt LW, Haenen GR, 1997. The use of human in vitro metabolic parameters to explore the risk assessment of hazardous compounds: The case of ethylene dibromide. Toxicol Appl Pharmacol 143(1):56–69. 10.1006/taap.1996.8004.9073592
*Plotnick HB, Conner WL. 1976. Tissue distribution of ^14^C-labeled ethylene dibromide in the guinea pig. Pharmacology 13:251–258.
*Plotnick HB, Weigel WW, Richards DE, 1979. The effect of dietary disulfiram upon the tissue distribution and excretion of ^14^C-1,2-dibromoerhane in the rat. Res Commun Chem Pathol Pharmacol 26:535–543.392662
Pohl L, Gillette J. 1984–1985. Determination of toxic pathways of metabolism by deuterium substitution. Drug Metab Rev 15:1335–1351.6398777
*Prakash MS, Sud K, Kohli HS, 1999. Case report: Ethylene dibromide poisoning with acute renal failure: First reported case with non-fatal outcome. Ren Fail 21(2):219–222.10088182
*Pranoto-Soetardhi LA, Rijk MAH, DeKruijf N, 1986. Automatic headspace sampling for determination of ethylene dibromide residues in cereals. Int J Environ Anal Chem 25:151–159.3528001
*Principe P, Dogliotti E, Bignami M, 1981. Mutagenicity of chemicals of industrial and agricultural relevance in Salmonella, Streptomyces and Aspergillus. J Sci Food Agric 32:826–832.7026896
*Prodi G, Arfellini F, Colacci A, 1986. Interaction of halocompounds with nucleic acids. Toxicol Pathol 14:444.
Quillardet P, De Bellecombe C, Hofnung M. 1985. The SOS chromotest, a calorimetric bacterial assay for genotoxins: Validation study with 83 compounds. Mutat Res 147:79–95.3889610
Ramsey JC, Park CN, Ott MG, 1979. Carcinogenic risk assessment: Ethylene dibromide. Toxicol Appl Pharmacol 47:411–414.377566
Rannug U. 1980. Genotoxic effects of 1,2-dibromoethane and 1,2-dichloroethane. Mutat Res 76:269–295.7010129
Rannug U, Beije B. 1979. The mutagenic effect of 1,2-dichloroethane on Salmonella typhimurium. Part II. Activation by the isolated perfused rat liver. Chem-Biol Interact 24:265–286.371841
Rannug U, Sundvall A, Ramel C. 1978. The mutagenic effect of 1,2-dichloroethane on Salmonella typhimurium. Part I. Activation through conjugation with glutathione in vitro. Chem Biol Interact 20:1–16.24503
*Rasmussen RA, Khalil MAK. 1984. Gaseous bromine in the arctic and arctic haze. Geophys Res Lett 11:433–436.
*Ratcliffe JM, Schrader SM, Steenland K, 1987. Semen quality in papaya workers with long term exposure to ethylene dibromide. Br J Ind Med 44:317–326.3297130
Ratcliffe JM, Schrader SM, Turner TW, 1986. The use of new field methods of semen analysis in the study of occupational hazards to reproduction: The example of ethylene dibromide. The changing nature of work and workforces. Proceedings of the Third Joint US-Finnish Science Symposium, Frankfort, Kentucky October 22-24,1986. Cincinnati, OH: National Institute for Occupational Safety and Health (NIOSH), 103–106.
*Rathbun RE, Tai DY. 1986. Gas-film coefficients for the volatilization of ethylene dibromide from water. Environ Sci Technol 20:949–952.22263830
Rathbun RE, Tai DY. 1987. Volatilization of ethylene dibromide from water. Environ Sci Technol 21:248–252.22185102
Reed NR, Narloch BA, Olsen HE, 1987. Health risk assessment of 1,2-dibromoethane (EDB) in California drinking water. Gov Rep Announce Index. Davis, CA: California Public Health Foundation. PB88169701.
*Reznik G, Stinson SF, Ward JM. 1980. Respiratory pathology in rats and mice after inhalation of 1,2-dibromo-3-chloropropane or 1,2-dibromoethane for 13 weeks. Arch Toxicol 46:233–240.7016076
Rinkus SJ, Legator MS. 1985. Fluorometric assay using high-pressure liquid chromatography for the microsomal metabolism of certain substituted aliphatics to 1,N-6 ethenoadenine-forming metabolites. Anal Biochem 150:379–393.3004254
*Rogers RD, McFarlane JC. 1981. Sorption of carbon tetrachloride, ethylene dibromide, and trichloroethylene on soil and clay. Environ Monit Assess 1:155–162.24263810
*Roldan-Arjona T, Garcia-Pedrajas MD, Luque-Romero FL, 1991. An association between mutagenicity of the Ara test of Salmonella typhimurium and carcinogenicity in rodents for 16 halogenated aliphatic hydrocarbons. Mutagenesis 6(3):199–206.1881351
Rosenberg MJ, Feldblum PJ, Marshall EG. 1987. Occupational influences on reproduction: A review of recent literature. J Occup Med 29:584–591.3612335
*Rosenkranz HS. 1977. Mutagenicity of halogenated alkanes and their derivatives. Environ Health Perspect 21:79–84.348460
*Ross MK, Pegram RA. 2003. [^35^S]-Labeling of the Salmonella typhimurium glutathione pool to assess glutathione-mediated DNA binding by 1,2-dibromoethane. Chem Biol Interact 146(1):39–49.12902151
Rowe VK, Hollingsworth RL, McCollister DD. 1954. Pesticide toxicity: Toxicity study of a grain fumigant (Dowfume EB-5). J Agric Food Chem 2:1318–1323.
*Rowe VK, Spencer HC, McCollister DD, 1952. Toxicity of ethylene dibromide determined on experimental animals. Ind Hyg Occup Med 6:158–173.
*Rumsey DW, Tanita RK. 1978. An industry-wide industrial hygiene study of ethylene dibromide. Cincinnati, Ohio: National Institute for Occupational Safety and Health. DHEW/PUB/NIOSH-79/112. PB297773.
*Rush GF, Smith JH, Newton JF, 1984. Chemically-induced nephrotoxicity: Role of metabolic activation. CRC Crit Rev Toxicol 13:99–160.
*Rydell, CD. 1990. Written communication (March 27) to Barry L. Johnson. Agency for Toxic Substances and Disease Registry, regarding North Dakota air contaminant limits. Bismark, ND: North Dakota State Department of Health and Consolidated Laboratories.
*Santodonato J, Bosch S, Meylan W, 1985. Monograph on human exposure to chemicals in the workplace: Ethylene dibromide (EDB). Center for Chemical Hazard Assessment. Syracuse, New York: Syracuse Research Corporation. SRC TR 84–622.
*Saraswat PK, Kandara M, Dhurva AK, 1986. Poisoning by ethylene dibromide-six cases: A clinicopathological and toxicological study. Indian J Med Sci 40:121–123.3533772
*Sasaki YF, Saga A, Akasaka M, 1998. Detection of in vivo genotoxicity of haloalkanes and haloalkenes carcinogenic to rodents by the alkaline single cell gel electrophoresis (comet) assay in multiple mouse organs. Mutat Res 419(1–3):13–20.9804871
*Sawhney BL, Pignatello JJ, Steinberg SM. 1988. Determination of 1,2-dibromoethane (EDB) in field soils: Implications for volatile organic compounds. J Environ Qual 17:149–152.
*Sax I, ed. 1989. Dangerous properties of industrial materials. 6 ed. New York, NY: Van Nostrand Reinhold Company.
*Schlinke JC. 1969. Toxicologic effects of five soil nematocides in cattle and sheep. J Am Vet Med Assoc 155:1364–1366.5633910
*Schmezer P, Eckert C, Liegibel UM, 1998. Mutagenic activity of carcinogens detected in transgenic rodent mutagenicity assays at dose levels used in chronic rodent cancer bioassays. Mutat Res 405(2):193–198.9748572
Schoenberg JB, Stemhagen A, Mason TJ, 1987. Occupation and lung-cancer risk among New Jersey white males. J Natl Cancer Inst 79:13–21.3474440
Schrader SM, Ratcliffe JM, Turner TW, 1987. The use of new field methods of semen analysis in the study of occupational hazards to reproduction: The example of ethylene dibromide. J Occup Med 29:963–966.3323429
*Schrader SM, Turner TW, Ratcliffe JM. 1988. The effects of ethylene dibromide on semen quality: A comparison of short-term and chronic exposure. Reprod Toxicol 2(3):191–198. 10.1016/0890-6238(88)90021-4.2980345
Schrag SD, Dixon RL. 1985. Occupational exposures associated with male reproductive dysfunction. Ann Rev Pharmacol Toxicol 25:567–592.2408559
Scott BR, Sparrow AJ, Schwemmer SS, 1978. Plant metabolic activation of 1,2-dibromoethane (EDB) to a mutagen of greater potency. Mutat Res 49:203–212.
*Scott DR, Dunn WJ III, Emery SL. 1987. Classification and identification of hazardous organic compounds in ambient air by pattern recognition of mass spectral data. Environ Sci Technol 21:891–897.
*Scudamore KA. 1985. Gas chromatographic determination of chloroform, carbon tetrachloride, ethylene dibromide and trichloroethylene in cereal grains after distillation. IARC Sci Pub1 68:361–367.
Shah JJ, Heyerdahl EK. 1988. National ambient volatile organic compounds (VOCs) database update. Research Triangle Park, NC: U.S. Environmental Protection Agency, Atmospheric Sciences Research Laboratory. EPA600S388010, 1–11.
*Sherratt PJ, Manson MM, Thomson AM, 1998. Increased bioactivation of dihaloalkanes in rat liver due to induction of class Theta glutathione S-transferase T1-1. Biochem J 335(3):619–630.9794803
*Shiau SY, Huff RA, Wells BC, 1980. Mutagenicity and DNA-damaging activity for several pesticides tested with Bacillus subtilis mutants. Mutat Res 71:169–179.6771645
Shih TW, Hill DL. 1981. Metabolic activation of 1,2-dibromoethane by glutathione transferase and by microsomal mixed function oxidase: Further evidence for formation of two reactive metabolites. Res Commun Chem Pathol Pharmacol 33:449–461.7036301
Shikiya J, Tsou G, Kowalski J, 1984. Ambient monitoring of selected halogenated hydrocarbons and benzene in the California south coast air basin. Proc APCA Annu Meet 1:21.
Shirasu Y, Moriya M, Tezuka H, 1984. Mutagenicity of pesticides. Environ Sci Res 31:617–624.
*Shivanandappa T, Krishnakumari MK, Majumder SK. 1987. Reproductive potential of male rats fed dietary ethylene dibromide. Blackwell Publishing Ltd. J Food Saf 8(3):147–155. 10.1111/j.1745-4565.1987.tb00560.x.
*Short RD, Minor JL, Winston HM, 1978. Inhalation of ethylene dibromide during gestation by rats and mice. Toxicol Appl Pharmacol 46:173–182.364772
Short RD, Minor JL, Winston JM, 1977. Task IV. Developmental toxicity of ethylene dibromide inhaled by rats and mice during organogenesis. Toxicity studies of selected chemicals. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances. EPA560677028. PB273267, 1-15 117–127.
*Short RD, Winston JM, Hong CB, 1979. Effects of ethylene dibromide on reproduction in male and female rats. Toxicol Appl Pharmacol 49:97–105.382441
*Simmonds PG. 1984. Analysis of trace halocarbons in natural waters by simplified purge and cytotrap method. J Chromatogr 289:117–127.
*Simula TP, Glancey MJ, Wolf CR. 1993. Human glutathione S-transferase-expressing Salmonella typhimurium tester strains to study the activation/detoxification of mutagenic compounds: Studies with halogenated compounds, aromatic amines and aflatoxin B1. Carcinogenesis 14(7):1371–1376.8330352
Singh G, Rigney CF, Gilbert WS. 1979. Ethylene dibromide and inorganic bromide residues in oranges after fumigation and storage. Aust J Exp Agric Anim Husb 19:377–381.
Singh G, Rippon LE, Gilbert WS, 1976. Inorganic bromide residue in bananas, bell capsicums (sweet peppers), cherries and apples following fumigation with ethylene dibromide and methyl bromide. Aust J Exp Agric Anim Husb 16:780–784.
*Singh HB, Salas TJ, Shigeishi H. 1981. Atmospheric measurements of selected hazardous organic chemicals. Research Triangle Park, NC: U.S. Environmental Protection Agency, Environmental Sciences Research. EPA600S38132, 1–7.
*Singh S, Gupta A, Sharma S, 2000. Non-fatal ethylene dibromide ingestion. Hum Exp Toxicol 19(2):152–153. 10.1191/096032700678815675.10773847
*Sipes IG, Gandolfi AJ. 1986b. Chapter 4 biotransformation of toxicants. In: Klaassen CD, Admur MO, Doull J, eds. Casarett and Doull’s toxicology: The basic science of poisons. 3rd ed. New York NY: Macmillan Publishing Company, 64–98.
*Sipes IG, Wiersma DA, Armstrong DJ. 1986a. The role of glutathione in the toxicity of xenobiotic compounds: Metabolic activation of 1,2-dibromoethane by glutathione. Adv Exp Med Biol 197:457–467.3532707
Sittig M, ed. 1979. 1,2-Dibromoethane. Hazardous and toxic effects of industrial chemicals. NJ: Noyes Data Corp, 163–166.
*Smith RF, Goldman L. 1983. Behavioral effects of prenatal exposure to ethylene dibromide. Neurobehav Toxicol Teratol 5:579–585.6363954
Snelson A, Butler R, Jarke F. 1978. Study of removal processes for halogenated air pollutants. Research Triangle Park, NC: U.S. Environmental Protection Agency, Environmental Sciences Research Lab. EPA600378058.
Stampfer JF. 1982. Respirator canister evaluation for nine selected organic vapors. Am Ind Hyg Assoc J 43:319–328.
State of Wisconsin Department of Natural Resources. 1988a. Wisconsin Administrative Code. Control of hazardous pollutants. Chapter NR 445. Register No. 393.
State of Wisconsin Department of Natural Resources. 1988b. Wisconsin Administrative Code. Groundwater quality. Chapter NR 140. Register No. 394.
State of Vermont Agency of Natural Resources. 1988. Chapter 12. Ground water protection rule and strategy. Vermont: State of Vermont, Agency of Natural Resources, Department of Environmental Conservation. 099/1100/GW2, 28.
*Steenland K, Carrano A, Clapp D, 1985. Cytogenetic studies in humans after short-term exposure to ethylene dibromide. J Occup Med 27:729–732.3906053
*Steenland K, Carrano A, Ratcliffe J, 1986. A cytogenetic study of papaya workers exposed to ethylene dibromide. Mutat Res 170:151–160.3520305
*Steinberg SM, Pignatello JJ, Sawhney BL. 1987. Persistence of 1,2-dibromoethane in soils: Entrapment in intraparticle micropores. Environ Sci Technol 21:1201–1208.
*Stenger VA. 1978. Bromine compounds. In: Kirk-Othmer encyclopedia of chemical technology. 3^rd^ ed., Vol. 4. New York, NY: Wiley-Interscience, 243–263.
*Stinson SF, Reznik G, Ward JM. 1981. Characteristics of proliferative lesions in the nasal cavities of mice following chronic inhalation of 1,2-dibromoethane. Cancer Lett 12:121–129.7023670
*Stolzenberg SJ, Hine CH. 1980. Mutagenicity of 2- and 3-carbon halogenated compounds in the Salmonella/mammalian-microsome test. Environ Mutagen 2:59–66.7035158
*Stoner GD, Conran PB, Greisiger EA, 1986. Comparison of two routes of chemical administration on the lung adenoma response in Strain A/J mice. Toxicol Appl Pharmacol 82:19–31.3945940
*Storer RD, Conolly RB. 1983. Comparative in vivo genotoxicity and acute hepatotoxicity of three 1,2-dihaloethanes. Carcinogenesis 4:1491–1494.6357525
*Storer RD, McKelvey TW, Kraynak AR, 1996. Revalidation of the in vitro alkaline elution/rat hepatocyte assay for DNA damage: Improved criteria for assessment of cytotoxicity and genotoxicity and results for 81 compounds. Mutat Res 368(2):59–101.8684406
*Stott WT, McKenna MJ. 1984. The comparative absorption and excretion of chemical vapors by the upper, lower, and intact respiratory tract of rats. Fundam Appl Toxicol 4:594–602.6479505
*Stutz DR, Janusz SJ. 1988. Hazardous materials injuries. Beltsville, MD: Bradford Communications Corp., 300–301.
Sullivan FM, Barlow SM. 1985. The relevance for man of animal data on reproductive toxicity of industrial chemicals. Prevention of physical and mental congenital defects, Part B: Epidemiology, early detection and therapy, and environmental factors. Alan R. Liss, Inc.
Sundheimer DW, White R, Sipes IG, 1981. Nucleic acid alkylation and production of DNA strand breaks by ethylene dibromide in isolated rat hepatocytes. Fed Proc Fed Am Soc Exp Biol 40:688.
*Sundheimer DW, White RD, Brendel K, 1982. The bioactivation of 1,2-dibromoethane in rat hepatocytes: Covalent binding to nucleic acids. Carcinogenesis 3:1129–1133.6184181
*Sweeney MH, Beaumont JJ, Waxweiler RJ, 1986. An investigation of mortality from cancer and other causes of death among workers employed at an east Texas chemical plant. Arch Environ Health 41(1):23–28.3963883
*Tamura S, Sugiyama T, Minami Y, 1986. Analysis of debromination of 1,2-dibromoethane by cytochrome P-450-linked hydroxylation systems as observed by bromide electrode. J Biochem 99:163–171.3514588
*Tan EL, Hsie AW. 1981. Mutagenicity and cytotoxicity of haloethanes as studied in the CHO/HGPRT system. Mutat Res 90:183–191.7035935
Tennant RW, Margolin BH, Shelby MD, 1987. Prediction of chemical carcinogenicity in rodents from in vitro genetic toxicity assays. Science 236:933–941.3554512
*Ter Haar G. 1980. An investigation of possible sterility and health effects from exposure to ethylene dibromide. In: Ames B, Infante P, and Reitz R, eds. Cold Spring Harbor NY: Banbury Report. Vol. 5. Cold Spring Harbor Laboratory, 167–188.
*Teramoto S, Saito R, Aoyama H, 1980. Dominant lethal mutation induced in male rats by 1,2-dibromo-3-chloropropane (DBCP). Mutat Res 77:71–78.6987512
*Tezuka H, Ando N, Suzuki R, 1980. Sister chromatid exchanges and chromosomal aberrations in cultured Chinese hamster cells treated with pesticides positive in microbial reversion assays. Mutat Res 78:177–191.7393245
*Thier R, Pemble SE, Kramer H, 1996. Human glutathione S-transferase T1-1 enhances mutagenicity of 1,2-dibromoethane, dibromomethane and 1,2,3,4-diepoxybutane in Salmonella typhimurium. Carcinogenesis 17(1):163–166.8565128
*Thier R, Taylor JB, Pemble SE, 1993. Expression of mammalian glutathione S-transferase 5-5 in Salmonella typhimurium TA1535 leads to base-pair mutations upon exposure to dihalomethanes. Proc Natl Acad Sci USA 90(18):8576–8580.8378332
*Thomas C, Will Y, Schoenberg SL, 2001. Conjugative metabolism of 1,2-dibromoethane in mitochondria: Disruption of oxidative phosphorylation and alkylation of mitochondrial DNA. Biochem Pharmacol 61(5):595–603.11239503
Tokoro R, Osteryoung J. 1982. [Study of the reduction mechanism of 1,2-dibromothane by reverse pulse polarography]. An Sim Bras Eletroquim Eletroanal 1:307–316. (Spanish)
*Tomasi A, Albano E, Bini A, 1984. Free radical intermediates under hypoxic conditions in the metabolism of halogenated carcinogens. Toxicol Pathol 12:240–246.6393297
*Tomasi A, Albano E, Dianzani MU, 1983. Metabolic activation of 1,2-dibromoethane to a free radical intermediate by rat liver microsomes and isolated hepatocytes. FEBS Lett 160:191–194.6350040
*TRI16. 2017. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Office of Information Analysis and Access. Office of Environmental Information. U.S. Environmental Protection Agency. Toxics Release Inventory. http://www.epa.gov/triexplorer/. October 14, 2017.
Tsani-Bazaca E, McIntyre AE, Lester JN, 1981. Concentrations and correlations of 1,2-dibromoethane, 1,2-dichloroethane, benzene, and toluene in vehicle exhaust and ambient air. Environ Technol Lett 2:303–316.
*Tucker JD, Auletta A, Cimino MC, 1993. Sister-chromatid exchange: Second report of the Gene-Tox Program. Mutat Res 297(2):101–180.7687323
*Tucker JD, Xu J, Stewart J, 1984. Detection of sister-chromatid exchanges in human peripheral lymphocytes induced by ethylene dibromide vapor. Mutat Res 138:93–98.6387481
*Turner D, Barry PSI. 1979. An epidemiological study of workers in plants manufacturing ethylene dibromide. Arh hig rada toksikol 30 (suppl):621–626.
USDA. 1988. U.S. Department of Agriculture. Fed Regist 53:16538–16539.
Vamvakas S, Elfarra AA, Dekant W, 1988. Mutagenicity of amino-acid and glutathione S-conjugates in the Ames test. Mutat Res 206:83–90.2901035
*Van Bladeren PJ. 1983. Metabolic activation of xenobiotics: Ethylene dibromide and structural analogs. J Am Coll Toxicol 2(3):73–83.
*Van Bladeren PJ, Breimer DD, Rotteveel-Smijs GMT, 1980. The role of glutathione conjugation in the mutagenicity of 1,2-dibromoethane. Biochem Pharmacol 29:2975–2982.7006609
*Van Bladeren PJ, Breimer DD, Rotteveel-Smijs GM, 1982. The activating role of glutathione in the mutagenicity of 1,2-dibromoethane. Adv Exp Med Biol 136:809–820.
*Van Bladeren PJ, Breimer DD, Van Huijgevoort JA, 1981. The metabolic formation of N-acetyl-S-2-hydroxyethyl-L-cysteine from tetradeutero-1,2-dibromoethane. Relative importance of oxidation and glutathione conjugation in vivo. Biochem Pharmacol 30:2499–2502.21043256
*Van Duuren BL, Goldschmidt BM, Loewengart G, 1979. Carcinogenicity of halogenated olefinic and aliphatic hydrocarbons in mice. J Natl Cancer Inst 63:1433–1439.292813
*Van Duuren BL, Melchionne S, Seidman I, 1986. Chronic bioassays of chlorinated humic acids in B6C3F_l_ mice. Environ Health Perspect 69:109–117.2949967
*Van Duuren BL, Seidman I, Melchionne S, 1985. Carcinogenicity bioassays of bromoacetaldehyde and bromoethanol-potential metabolites of dibromoethane. Teratog Carcinog Mutagen 5:393–403.2874625
*Van Iersel AAJ, Vanholsteijn I, Blaauboer BJ. 1988. Effects of 1,2-dibromoethane on isolated hepatocytes: Functional alterations and induction of lipid-peroxidation. Xenobiotica 18:675–683.3420945
*Van Rillaer WG, Beernaert H. 1985. Determination of residual ethylene dibromide in cereals by glass capillary gas chromatography. Z Lebensm Unters Forsch 180:284–288.3890409
*van Welie RTH, van Dijck R, Vermeulen NPE. 1992. Mercapturic acids, protein adducts, and DNA adducts as biomarkers of electrophilic chemicals. CRC Crit Rev Toxicol 22(6):271–306.
*Venkat JA, Shami S, Davis K, 1995. Relative genotoxic activities of pesticides evaluated by a modified SOS microplate assay. Environ Mol Mutagen 25(1):67–76.7875128
Venkateswarlu P, Manjubhashni AB, Kumari SR, 1987. Volumetric behavior of an alcohol with 1,2-dibromoethane. Phys Chem Liq 16:225–230.
*View Database. 1989. Agency for Toxic Substances and Disease Registry (ATSDR), Office of External Affairs, Exposure and Disease Registry Branch, Atlanta, GA. September 25, 1989.
Vineis P, Thomas T, Hayes RB, 1988. Proportion of lung cancers in males, due to occupation, in different areas of the USA. Int J Cancer 42:851–856.3192330
*Vogel E, Chandler JLR. 1974. Mutagenicity testing of cyclamate and some pesticides in Drosophila melanogaster. Experientia 30:621–623.4209504
*Vogel EW, Nivard MJ. 1993. Performance of 181 chemicals in a Drosophila assay predominantly monitoring interchromosomal mitotic recombination. Mutagenesis 8(1):57–81.8450769
Vogel EW, Zijlstra JA. 1987. Mechanistic and methodological aspects of chemically-induced somatic mutation and recombination in Drosophila melanogaster. Mutat Res 182:243–264.3116423
*Vogel TM, Reinhard M. 1986. Reaction products and rates of disappearances of simple bromoalkanes, 1,2-dibromopropane, and 1,2-dibromoethane in water. Environ Sci Technol 20:992–997.22257396
*Vogel EW, Nivard MJ, Ballering LA, 1996. DNA damage and repair in mutagenesis and carcinogenesis: Implications of structure-activity relationships for cross-species extrapolation. Mutat Res 353(1–2):177–218.8692191
Wallace LA, Pellizzari E, Hartwell T, 1984. Personal exposure to volatile organic compounds. I. Direct measurements in breathing-zone air, drinking water, food, and exhaled breath. Environ Res 35:293–319.6489295
*Wallace L, Zweidinger R, Erickson M, Cooper S, 1982. Monitoring individual exposure. Measurements of volatile organic compounds in breathing-zone air, drinking water, and exhaled breath. Environ Int 8:269–282.
*Watanabe K, Liberman RG, Skipper PL, 2007. Analysis of DNA adducts formed in vivo in rats and mice from 1,2-dibromoethane, 1,2-dichloroethane, dibromomethane, and dichloromethane using HPLC/accelerator mass spectrometry and relevance to risk estimates. Chem Res Toxicol 20(11):1594–1600. 10.1021/tx700125p.17907789
*Watanabe K, Sasaki T, Kawakami K. 1998. Comparisons of chemically-induced mutation among four bacterial strains, Salmonella typhimurium TA102 and TA2638, and Escherichia coli WP2/pKM101 and WP2 uvrA/pKM101: Collaborative study III and evaluation of the usefulness of these strains. Mutat Res 416(3):169–181.9729366
Watanabe PG, Young JD, Schlachter MM, 1978. Fate of inhaled ethylene dibromide in rats. Toxicol Appl Pharmacol 45:224.
*Weiss G, ed. 1986. Hazardous substances data book. 2nd ed. Park Ridge, NJ: Noyes Data Corporation.
White RD. 1982. Chemical induction of genetic injury: The bioactivation of 1,2-dibromoethane. Diss Abstr Int 43:696–698.
*White RD, Gandolfi AJ, Bowden GT, 1983. Deuterium isotope effect on the metabolism and toxicity of 1,2-dibromoethane. Toxicol Appl Pharmacol 69:170–178.6346586
White RD, Sipes IG, Gandolfi AJ, 1980. Determination of ethylene bromide induced DNA injury by alkaline elution. Fed Proc Fed Am Soc Exp Biol 39:1022.
*WHO. 2004. 1,2-Dibromoethane in drinking-water: Background document for development of WHO guidelines for drinking-water quality. Geneva, Switzerland: World Health Organization. http://www.who.int/water_sanitation_health/dwq/chemicals/ethylenedibromide.pdf. November 14, 2017.
*WHO. 2010. Guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. April 25, 2012.
*WHO. 2017. Guidelines for drinking-water quality. Fourth edition incorporating the first addendum. Geneva, Switzerland: World Health Organization. http://apps.who.int/iris/bitstream/10665/254637/1/9789241549950-eng.pdf?ua=1. February 28, 2017.
*Wiersma DA, Sipes IG. 1983. Metabolism of 1,2-dibromoethane by cytosol of rat liver, forestomach, and glandular stomach [Abstract]. Tox Lett 18(Suppl 1):155.
*Williams GM, Laspia MF, Dunkel VC. 1982. Reliability of the hepatocyte primary culture/DNA repair test in testing of coded carcinogens and noncarcinogens. Mutat Res 97:359–370.7144803
*Williams WM, Holden PW, Parsons DW, 1988. Pesticides in groundwater data base: 1988 Interim Report. Washington, DC: U.S. Environmental Protection Agency. PB89164230.
*Windholz M, ed. 1983. The Merck index. 10th ed. Rahway, NJ: Merck & Co., Inc.
Winston JM, Hong CB, Lee CC, 1979. Effect of 3- or 6-month inhalation of 1,2-dibromoethane in rats treated with disulfiram [Abstract]. Toxicol Appl Pharmacol 48:A25.
*Wong LC, Winston JM, Hong CB, 1982. Carcinogenicity and toxicity of 1,2-dibromoethane in the rat. Toxicol Appl Pharmacol 63:155–165.7046137
*Wong O, Utidjian MD, Karten VS. 1979. Retrospective evaluation of reproductive performance of workers exposed to ethylene dibromide (EDB). J Occup Med 21:98–102.372505
Working PK, Smith-Oliver T, Butterworth BE. 1985. Glutathione dependent induction of unscheduled DNA synthesis by ethylene dibromide in rat spermatocytes and hepatocytes. J Cell Biol Vol. 101, 462A.
*Working PK, Smith-Oliver T, White RD, 1986. Induction of DNA repair in rat spermatocytes and hepatocytes by 1,2-dibromoethane: The role of glutathione conjugation. Carcinogenesis 7:467–472.3512119
*Wormhoudt LW, Ploemen JH, Commandeur JN, 1996a. Cytochrome P450 catalyzed metabolism of 1,2-dibromoethane in liver microsomes of differentially induced rats. Chem Biol Interact 99(1–3):41–53.8620578
*Wormhoudt LW, Ploemen JH, de Waziers I, 1996b. Inter-individual variability in the oxidation of 1,2-dibromoethane: Use of heterologously expressed human cytochrome P450 and human liver microsomes. Chem Biol Interact 101(3):175–192.8870687
*Wyrobek AJ. 1984. Identifying agents that damage human spermatogenesis: Abnormalities in sperm concentration and morphology. Monitoring human exposure to carcinogenic and mutagenic agents. Lyon, France: IARC Sci Publ 59:387–402.
*Zeiger E, Anderson B, Haworth S, 1992. Salmonella mutagenicity tests: V. Results from the testing of 311 chemicals. Environ Mol Mutagen 21:2–141.
Zijlstra JA, Vogel EW. 1988. The ratio of induced recessive lethals to ring-x loss has prognostic value in terms of functionally of chemical mutagenesis in Drosophila melanogaster. Mutat Res 201:27–38.2458528
*Zoetemelk CEM, Mohn GR, Van DerGen A, 1987. 1,2-Dibromo compounds: Their mutagenicity in Salmonella strains differing in glutathione content and their alkylating potential. Biochem Pharmacol 36:1829–1835.3555505
Zweidinger R, Erickson M, Cooper S, 1982. Direct measurement of volatile organic compounds in breathing-zone air, drinking water, breath, blood, and urine. Washington, DC: U.S. Environmental Protection Agency. EPA600482015.