# CONTRIBUTORS & REVIEWERS

## CHEMICAL MANAGER TEAM

- Rae T. Benedict, Ph.D.
- ATSDR, Division of Toxicology and Human Health Sciences, Atlanta, GA
- Julie M. Klotzbach, Ph.D.
- SRC, Inc., North Syracuse, NY

## REVIEWERS

Interagency Minimal Risk Level Workgroup:

Includes ATSDR; National Center for Environmental Health (NCEH); National Institute of Occupational Health and Safety (NIOSH); U.S. Environmental Protection Agency (EPA); National Toxicology Program (NTP).

Additional reviews for science and/or policy:

ATSDR, Division of Community Health Investigations; ATSDR, Office of Science; NCEH, Division of Laboratory Science; NCEH, Division of Environmental Health Science and Practice.