# VERSION HISTORY

Date | Description
September 2018 | Update of the Relevance to Public Health, Health Effects, and Regulations and Advisories
July 1992 | Final toxicological profile released