# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding 1,2-dibromoethane in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for 1,2-dibromoethane.

Table 7-1 Regulations and Guidelines Applicable to 1,2-Dibromoethane

Agency | Description | Information | Reference
Air
EPA | RfC | 9×10^−3^ mg/m^3^ | IRIS 2004
WHO | Air quality guidelines | No data | WHO 2010
Water & Food
EPA | RfD | 9×10^−3^ mg/kg/day | IRIS 2004
EPA | Drinking water standards and health advisories | | EPA 2012
EPA | 1-Day health advisory (10-kg child) | 0.008 mg/L | EPA 2012
EPA | 10-Day health advisory (10-kg child) | 0.008 mg/L | EPA 2012
EPA | DWEL | 0.3 mg/L | EPA 2012
EPA | National primary drinking water regulations | | EPA 2009
EPA | MCL | 0.00005 (mg/L) | EPA 2009
WHO | Drinking water quality guidelines | 0.0004 mg/L (0.4 μg/L) (provisional) | WHO 2004, 2017
FDA | EAFUS | No data^a^ | FDA 2013
FDA | Allowable level in bottled water | 0.00005 mg/L | FDA 2017
Cancer
HHS | Carcinogenicity classification | Reasonably anticipated to be a human carcinogen | NTP 2016
EPA | Carcinogenicity classification | Likely to be carcinogenic to humans | IRIS 2004
EPA | Inhalation unit risk, 95% upper bound | 6×10^−4^ (μg/m^3^)^−1^ | IRIS 2004
EPA | Oral slope factor, 95% upper bound | 2×10^0^ (mg/kg-day)^−1^ | IRIS 2004
IARC | Carcinogenicity classification | Group 2A^b^ | IARC 1999
Occupational
OSHA | PEL for general industry | | OSHA 2016b
OSHA | 8-hour TWA | 20 ppm | OSHA 2016b
OSHA | Acceptable ceiling concentration | 30 ppm | OSHA 2016b
OSHA | Maximum peak (5-minute)^c^ | 50 ppm | OSHA 2016b
OSHA | PEL (ceiling limit) for shipyards and construction | (C)25 ppm^d^ | OSHA 2016a, 2017
NIOSH | REL | | NIOSH 2016
NIOSH | TWA (up to 10 hours) | 0.045 ppm | NIOSH 2016
NIOSH | Ceiling (15-minute) | 0.13 ppm | NIOSH 2016
| IDLH | 100 ppm | NIOSH 1994
Emergency Criteria
EPA | AEGLs-air | | EPA 2016
EPA | AEGL 1 | | EPA 2016
EPA | 10 minute | 52 ppm | EPA 2016
EPA | 30 minute | 26 ppm | EPA 2016
EPA | 60 minute | 17 ppm | EPA 2016
EPA | 4 hour | 7.1 ppm | EPA 2016
EPA | 8 hour | 4.6 ppm | EPA 2016
EPA | AEGL 2 | | EPA 2016
EPA | 10 minute | 73 ppm | EPA 2016
EPA | 30 minute | 37 ppm | EPA 2016
EPA | 60 minute | 24 ppm | EPA 2016
EPA | 4 hour | 10 ppm | EPA 2016
EPA | 8 hour | 6.5 ppm | EPA 2016
EPA | AEGL 3 | | EPA 2016
EPA | 10 minute | 170 ppm | EPA 2016
EPA | 30 minute | 76 ppm | EPA 2016
EPA | 60 minute | 46 ppm | EPA 2016
EPA | 4 hour | 17 ppm | EPA 2016
EPA | 8 hour | 10 ppm | EPA 2016
DOE | PACs-air | | DOE 2016b
DOE | PAC-1^e^ | 17 ppm | DOE 2016b
DOE | PAC-2^e^ | 24 ppm | DOE 2016b
DOE | PAC-3^e^ | 46 ppm | DOE 2016b

a The EAFUS list of substances contains ingredients added directly to food that FDA has either approved as food additives or listed or affirmed as GRAS.

b Group 2A: probably carcinogenic to humans.

c Acceptable maximum peak, for a maximum duration of 5 minutes, above the acceptable ceiling concentration for an 8-hour shift.

d Skin designation

e Definitions of PAC terminology are available from U.S. Department of Energy (DOE 2016a).

AEGL = acute exposure guideline levels; DOE = Department of Energy; DWEL = Drinking Water Equivalent Level; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; GRAS = generally recognized as safe; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; IDLH = Immediately Dangerous to Life or Health; IRIS = Integrated Risk Information System; MCL = Maximum Contaminant Level; NIOSH = National Institute for

Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = Protective Action Criteria; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TWA = time-weighted average; WHO = World Health Organization