# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Data pertaining to the chemical identity of 1,2-dibromoethane are listed in Table 4-1.

Table 4-1 Chemical Identity of 1,2-Dibromoethane

Characteristic | Information | Reference
Chemical name | 1,2-Dibromoethane | Windholz 1983
Synonym(s) and registered trade name(s) | Ethylene dibromide; dibromoethane; HSDB 1989; Weiss 1986; ethylene bromide; ethane, 1,2-dibromo-; Windholz 1983 EDB; α-, β-dibromoethane; symdibromoethane; glycol bromide; glycol dibromide; 1,2-dibromoethano (Italian); bomoro ei etile (Italian); 1,2-dibroomethaan (Dutch); althylenbromid (German); dibromure d’ethylene (French); dwubromoetan (Polish); Bromofume; Dowfume W85; Dowfume EDB; Dowfume 40, W-10, W-15, W-40; Dowfume MC-2; Iscobrome D; ENT 15, 349; Netis; Pestmaster EDB-85; Santryuum; Unifume; EDB-85; Fumogas; Icopfume soilbrom-85; soilfume; DBE | HSDB 1989; Weiss 1986; Windholz 1983
Chemical formula | C_2_H_4_Br_2_; BrCH_2_CH_2_Br | Windholz 1983
Chemical structure | [image]
CAS Registry Number | 106-93-4 | Weiss 1986

CAS = Chemical Abstracts Service

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

The physical and chemical properties of 1,2-dibromoethane are presented in Table 4-2.

Table 4-2 Physical and Chemical Properties of 1,2-Dibromoethane

Property | Information | Reference
Molecular weight | 187.86; 187.88; 188.0 | Weiss 1986; Windholz 1983; NIOSH 1985
Color | Colorless | Weiss 1986
Physical state at 15°C, 1 atm | Liquid | Weiss 1986
Melting point | 10°C | NIOSH 1978
Boiling point | 131–132°C | Windholz 1983
Density at 25°C | 2.172 g/cm^3^ | Windholz 1983
Odor | Mild sweet odor, like chloroform | Weiss 1986
Odor threshold:
Water | No data
Air | No data
Solubility:
Water at 20°C | 0.4 g/100 g water | Weiss 1986
Water at 25°C | 0.429 g/100 g water | Parrish 1983
Organic solvents | Miscible with alcohol, ether | Windholz 1983
Partition coefficients:
Log K_ow_ | 86 | Steinberg et al. 1987
Log K_oc_ | 66 | Rogers and Mcfarlane 1981
Vapor pressure at 25°C | 11 mmHg | Windholz 1983
Henry’s law constant at 20°C | 8.2×10^−4^ atm m^3^/mol | Rathbun and Tai 1986
Autoignition temperature | Not flammable | Weiss 1986
Flashpoint | Not flammable | Weiss 1986
Flammability limits | Not flammable | Weiss 1986
Conversion factors | No data
Explosive limits | No data