# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (_≥_365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Human Health Sciences, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Division of Toxicology and Human Health Sciences, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-57, Atlanta, Georgia 30329-4027.

## 1,2-Dibromoethane Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2-Dibromoethane
CAS Numbers: | 106-93-4
Date: | July 1992; March 2017—Updated literature search
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL for 1,2-dibromoethane.

Rationale for Not Deriving an MRL: The available acute-duration inhalation studies were designed to assess lethality (Rowe et al. 1952) or developmental effects (Short et al. 1978) and did not evaluate comprehensive toxicological endpoints. At the lowest exposure level tested in acute-duration inhalation studies (20 ppm, 23 hours/day for gestational days 6–15), skeletal anomalies, a serious effect, were observed (Short et al. 1978). Therefore, data are not suitable for derivation of an acute-duration inhalation MRL.

Agency Contacts (Chemical Managers): Rae T. Benedict

## 1,2-Dibromoethane Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2-Dibromoethane
CAS Numbers: | 106-93-4
Date: | July 1992; March 2017—Updated literature search
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL for 1,2-dibromoethane.

Rationale for Not Deriving an MRL: Several studies have investigated effects of intermediate-duration inhalation exposure to 1,2-dibromoethane (Nitchke et al. 1981; NTP 1982; Reznik et al. 1980; Rowe et al. 1952; Short et al. 1979). Of these studies, NTP (1982) is the only study that conducted histopathological evaluations of comprehensive tissues. Two studies conducted histopathological assessments of selected tissues (Nitchke et al. 1981; Rowe et al. 1952), and other studies focused on specific endpoints, including respiratory effects (Reznik et al. 1980) and reproductive effects (Short et al. 1979). The lowest LOAELs for noncancer effects of intermediate-duration inhalation exposure to 1,2-dibromoethane for each system are summarized in Table A-1.

Changes in body weight in female mice were observed in all treatment groups, with a LOAEL value of 3 ppm. However, effects on body weight were inconsistent, with increases of 30 and 15% in the 3 and 15 ppm groups, respectively, and a 36% decrease in the 75 ppm group (NTP 1982). Therefore, alterations in body weight were not considered as the basis for the intermediate-duration MRL. Hyperplasia of nasal turbinates was observed in male and female rats, with NOAEL and LOAEL values of 3 and 10 ppm, respectively, for a 13-week exposure (Nitchke et al. 1981). Although hyperplasia is not a carcinogenic lesion, it is a proliferative lesion that is important in the development of cancer (EPA 2005). Since chronic-duration inhalation exposure to 10 ppm 1,2-dibromoethane produced adenomas and carcinomas in the nasal cavity in male and female rats (NTP 1982), it is possible that nasal cavity hyperplasia observed following 13 weeks of exposure may represent a precancerous event. Given this uncertainty, an intermediate-duration inhalation based on nasal cavity hyperplasia is not considered appropriate. Although hepatic and renal effects were observed in guinea pigs exposure to 50 ppm (NOAEL 25 ppm) (Rowe et al. 1952), these effects could not be used to derive an intermediate-duration MRL because death was observed in mice exposed to 20 ppm for 6 months (Adkins et al. 1986). Therefore, an intermediate-duration inhalation MRL has not been derived.

Table A-1 Effects in Rats and Mice Exposed to Inhaled 1,2-Dibromoethane for Intermediate Durations

Effect | Species (sex) | NOAEL (ppm) | LOAEL (ppm) | Reference
Respiratory, hyperplasia of nasal turbinates | Rat (M,F) | 3 | 10 | Nitchke et al. 1981
Body weight gain change | Rat (F) | - | 3 | NTP 1982
Death | Mouse (F) | ND | 20 | Adkins et al. 1986
Hepatic, fatty degeneration | Guinea pig (M) | 25 | 50 | Rowe et al. 1952
Renal, tubular degeneration, interstitial congestion, edema | Guinea pig (M,F) | 25 | 50 | Rowe et al. 1952
Ocular, irritation | Mouse (M,F) | 15 | 75 | NTP 1982
Endocrine, thyroid, decreased follicular size | Rat (M/F); Mouse (M,F) | 15 | 75 | NTP 1982
Endocrine, adrenal cortex, swelling and/or vacuolization | Rat (M,F) | 15 | 75 | NTP 1982
Reproductive, reduced fertility, degeneration of uterine epithelium | Rat (F) | 39 | 80 | Short et al. 1979
Reproductive, infertility, testicular atrophy | Rat (M) | 39 | 89 | Short et al. 1979

F = female; M = male; ND = not determined

Agency Contacts (Chemical Managers): Rae T. Benedict

## 1,2-Dibromoethane Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2-Dibromoethane
CAS Numbers: | 106-93-4
Date: | July 1992; March 2017—Updated literature search
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of an chronic-duration inhalation MRL for 1,2-dibromoethane.

Rationale for Not Deriving an MRL: The lowest nonlethal exposure level associated with adverse effects is for male reproductive effects in an occupational exposure of 46 fruit fumigation workers exposed to 0.088 ppm (time-weighted average) 1,2-dibromoethane for an average exposure duration of 5 years (Ratcliffe et al. 1987; Schrader et al. 1988). Schrader et al. (1988) noted that “moderate” dermal exposure also occurred in these workers. Compared to controls (n=43), significant decreases in sperm count (42% decrease; p<0.01) and the percentages of viable (11% decrease; p<0.01) and motile (24% decrease; p<0.01) sperm, and increases in abnormal sperm [tapered heads (69% increase; p<0.001), absent heads (45% increase; p<0.001), abnormal tails (14% increase; p<0.001)] were observed. Although the study report infers that the only chemical exposure was to 1,2-dibromoethane, the study report did not specifically state this. However, even with this uncertainty, a chronic-duration MRL could not be derived based on these data because effects are classified as a serious LOAEL.

All studies in laboratory animals were conducted at exposures levels of 10, 20, and 40 ppm, which are markedly higher than exposure levels in the human occupational studies (NTP 1982; Wong et al. 1982). Non-neoplastic effects observed at 10 ppm included nasal inflammation (female mice), spleen hemosiderosis (female mice), hepatic necrosis (male and female rats), adrenal cortical degeneration (female rats), retinal degeneration (female rats), and testicular degeneration (male rats) (NTP 1982). However, because excessive treatment-related deaths (31/50) also occurred in female mice at 10 ppm and a serious adverse effect (testicular degeneration) occurred in male rats exposed to 10 ppm, these data could not be used to derive a protective MRL. Data from male mice exposed to 10 ppm were not considered in the identification of adverse because of high mortality from urinary tract infections in control and treatment groups; this was not related to treatment (NTP 1982). The Wong et al. (1982) study saw effects at a higher concentration (20 ppm) and, therefore, was not considered further.

Agency Contacts (Chemical Managers): Rae T. Benedict

## 1,2-Dibromoethane Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2-Dibromoethane
CAS Numbers: | 106-93-4
Date: | July 1992; March 2017—Updated literature search
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL for 1,2-dibromoethane.

Rationale for Not Deriving an MRL: The available acute-duration oral exposure studies were designed to assess death (Rowe et al. 1952), gastrointestinal (Ghanayem et al. 1986), hepatic (Botti et al. 1986; Broda et al. 1979), or reproductive effects (Teramoto et al. 1980). As such, comprehensive toxicological endpoints were not examined in acute-duration oral exposure studies. The lowest lethality value reported was an LD_50_ value of 55 mg/kg (single dose) in rabbits (Rowe et al. 1952). Gastrointestinal and hepatic effects occurred at higher acute exposures. Fatty degeneration of the liver was observed in male rats exposed to 107 mg/kg (single dose) and forestomach proliferation and hyperkeratosis were observed in rats administered 80 mg/kg/day (5 days/week for 2 weeks). Dominant lethal mutagenicity tests were the only reproductive endpoint studied and there was no observable effect in male rats exposed up to 30 mg/kg/day or male mice exposed to up to 150 mg/kg/day. Because lethality was observed at the lowest acute oral exposure tested, data are not suitable for derivation of an acute-duration oral MRL.

Agency Contacts (Chemical Managers): Rae T. Benedict

## 1,2-Dibromoethane Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2-Dibromoethane
CAS Numbers: | 106-93-4
Date: | July 1992; March 2017—Updated literature search
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration oral MRL for 1,2-dibromoethane.

Rationale for Not Deriving an MRL: Two studies evaluated the effects of intermediate-duration oral exposure to 1,2-dibromoethane (NCI 1978; Shivanandappa et al. 1987). The NCI (1978) study conducted histopathological examinations of comprehensive tissues in male rats exposed to 38 mg/kg/day for 47 weeks. Although the exposure duration for this study was intended to be 2 years, treatment of male rats was terminated after 47 weeks due to excessive mortality (31/50 deaths); early mortality was not observed in control rats. NCI (1978) reported the following noncancerous adverse effects: hepatic peliosis, adrenal cortical degeneration, and testicular atrophy. The Shivananappa et al. (1987) study examined several tissues in a small number of male rats (5/group) exposed to 5–50 mg/kg/day for 90 days; no adverse effects were observed in any treatment group. An intermediate-duration oral MRL was not derived because excessive mortality occurred at the lowest dose tested (38 mg/kg/day) (NCI 1978).

Agency Contacts (Chemical Managers): Rae T. Benedict

## 1,2-Dibromoethane Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2-Dibromoethane
CAS Numbers: | 106-93-4
Date: | July 1992; March 2017—Updated literature search
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL for 1,2-dibromoethane.

Rationale for Not Deriving an MRL: Only one study evaluated noncancer effects of chronic-duration oral (gavage) exposure to 1,2-dibromoethane (NCI 1978); other chronic-duration studies evaluated body weight and cancer endpoints only (Van Duuren et al. 1985, 1986). Exposures in the NCI (1978) study were 37 mg/kg/day for 57 weeks in female rats and 62 and 107 mg/kg/day in male and female mice exposed for 53 weeks. Excessive mortality was observed in the NCI study; no early mortality was observed in controls. In female rats, 48/50 deaths occurred before treatment week 57; no noncancer effects were observed. In mice exposed to 62 mg/kg/day, 30/50 males died by week 58 and 22/50 females died by week 70. Effects observed in mice administered 62 mg/kg/day were depressed body weight gain (males and females), splenic hematopoiesis (females), liver inflammation (males), and alopecia and skin sores (males and females). However, due to excessive mortality at the lowest dose tested (37 mg/kg/day), a chronic-duration oral MRL was not derived.

Agency Contacts (Chemical Managers): Rae T. Benedict