# CHAPTER 8 REFERENCES

*Cited in text

*Ahmad N, Wisner JR., Warren DW. 1988. Morphological and biochemical changes in the adult male rat reproductive system following long-term treatment with 1,2-dibromo-3-chloropropane. Anat Ret 222:340–349.
*AIHA. 2015. Current ERPG Values (2015). Fairfax, VA: American Industrial Hygiene Association. https://www.aiha.org/get-involved/AIHAGuidelineFoundation/EmergencyResponsePlanningGuidelines/Documents/2015%20 ERPG%20Levels.pdf. March 22, 2016.
*Albanese R, Mirkova E, Gatehouse DG, . 1988. Species-specific response to the rodent carcinogens 1,2-dimethylhydrazine and 1,2-dibromo-3-chloropropane in rodent bone-marrow micronucleus assays. Mutagenesis 3(1):35–38.3282142
*Albrecht WN. 1987. Occupational exposure to 1,3-dichloropropene (TeloneII@) in Hawaiian pineapple culture. Arch Environ Health 42:286–291.3452296
*Albrecht WN, Chenchin K. 1985. Dissipation of 1,2-dibromo-3-chloropropanecis-1’,3-dichloropropene (1,3-DCP) and dichloropropenes from soil to atmosphere. Bull Environ Contam Toxicol 34:824–831.4016290
*Albrecht WN, Hagadone MR, Chenchin K. 1986. Charcoal air sampling tube storage stability and desorption efficiencies of 1,2-dibromo-3-chloropropane (DBCP) and 1,3-dichloropropene (DCP). Bull Environ Contam Toxicol 36:629–634.3697538
*Amann RP, Berndtson WE. 1986. Assessment of procedures for screening agents for effects on male reproduction: Effects of dibromochloropropane (DBCP) on the rat. Fundam Appl Toxicol 7:244–255.3758542
*Anonymous. 1988. DBCP. Rev Environ Contam Toxicol 104:73–91.3062703
*ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry. Fed Regist 54(174):37618–37634.
*ATSDR. 2017. 1,2-Dibromo-3-chloropropane. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry, Centers for Disease Control and Prevention. http://www.atsdr.cdc.gov/SPL/resources/index.html. October 6, 2017.
Axelson O. 1985. Halogenated alkanes and alkenes and cancer: Epidemiological aspects. In: Fishbein L, O’Neill I, eds. Environmental carcinogens selected methods of analysis. Lyon, France: World Health Organization, 7:5–20.
Barlow S, Sullivan F. 1982. Dibromochloropropane (DBCP). In: Reproductive hazards of industrial chemicals. London, England: Academic Press, 253–268.
*Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486.3222488
*Bartoov B, Ventura V, Ailenberg M, . 1987. Effects of dibromochloropropane and ethylene dibromide on biochemical events and ultramorphology of ejaculated ram spermatozoa in vitro. Am J Ind Med 11:647658.
Beattie P, Miller G, Brabec M, . 1984. Dibromochloropropane and methoxyacetic-acid alter lactate metabolism by isolated rat spermatocytes. Biol Reprod 30:169.
*Becher R, Lag M, Schwarze PE, . 1993. Chemically induced DNA damage in isolated rabbit lung cells. Mutat Res 285(2):303–311.7678904
*Bentley KS, Working PK. 1988. Activity of germ-cell mutagens and nonmutagens in the rat spermatocyte UDS assay. Mutat Res 203:135–142.3352642
Berndtson W, Neefus C, Foote R, . 1989. Optimal replication for histometric analyses of testicular function in rats or rabbits. Fundam Appl Toxicol 12:291–302.2714529
*Biava CG, Smuckler EA, Whorton D. 1978. The testicular morphology of individuals exposed to dibromochloropropane. Exp Mol Pathol 29:448–458.720550
Biles R. 1979. The toxicology and genetic toxicology of dibromochloropropane(DBCP). Diss Abst Int 39:5817.
*Biles RW, Connor TH, Trieff NM, . 1978. The influence of contaminants on the mutagenic activity of dibromochloropropane (DBCP). J Environ Pathol Toxicol 2:301–312.368282
*Bjorge C, Wiger R, Holme JA, . 1995. In vitro toxicity of 1,2-dibromo-3-chloropropane (DBCP) in different testicular cell types from rats. Reprod Toxicol 9(5):461–473.8563189
*Bjorge C, Wiger R, Holme JA, . 1996. DNA strand breaks in testicular cells from humans and rats following in vitro exposure to 1,2-dibromo-3-chloropropane (DBCP). Reprod Toxicol 10(1):51–59.8998386
*Bomberger DC, Gwinn JL, Mabey WR, . 1983. Environmental fate and transport at the terrestrial-atmospheric interface. American Chemical Society Symp Ser 225:197–214.
Borzsonyi M, Torok G, Pinter A, . 1984. Agriculturally-related carcinogenic risk. Models, mechanisms and etiology of tumor promotion. Lyon, France: World Health Organization. IARC Sci Pub1 56:465–486.
*Bouwer EJ, Wright JP. 1988. Transformations of trace halogenated aliphatics in anoxic biofilm columns. J Contam Hydrol 2:155–169.
*Brodzinsky R, Singh HB. 1982. Volatile organic chemicals in the atmosphere: An assessment of available data. Atmospheric Science Center, SRI International, Menlo Park, CA, 12, 19–21, 42.
*Bronstein AC, Currance PL. 1988. Emergency care for hazardous materials exposure. Washington DC: The CV Mosby Company, 155–156.
*Brunborg G, Holme JA, Soederlund EK, . 1988. An automated alkaline elution system: DNA damage induced by 1,2-dibromo-3-chloropropane in vivo and in vitro. Anal Biochem 174:522–536.3239754
*Brunborg G, Soderlund EJ, Holme JA, . 1996. Organ-specific and transplacental DNA damage and its repair in rats treated with 1,2-dibromo-3-chloropropane. Chem Biol Interact 101(1):33–48.8665617
Bull R. 1982. Experimental methods for evaluating the health risks associated with organic chemicals in drinking water. Toxicol Environ Chem 6:1–17.
Burek J, Murray F, Rao K, . 1979. Pathogenesis of inhaled 1,2-dibromo-3-chloropropane (DBCP) induced testicular atrophy in rats and rabbits. Toxicol Appl Pharmacol 48:A121.
*Burlinson NE, Lee LA, Rosenblatt DH. 1982. Kinetics and products of hydrolysis of 1,2-dibromo-3chloropropane. Environ Sci Technol 16:627–632.22284208
*Burmaster DE. 1982. The new pollution-groundwater contamination. Environment 24:7–13, 33–36.
*Bysshe SE. 1982. Bioconcentration factor in aquatic organisms. In: Lyman WJ, Reehl WF, Rosenblatt DH, eds. Handbook of chemical property estimation methods. Environmental behavior of organic compounds. New York, NY: McGraw-Hill Book Co., 5–5.
*Carter GE Jr., Riley MB. 1981. 1,2-Dibromo-3-chloropropane residues in water in South Carolina, 1979-80. Pest Monit J 15:139–142.
*Carter GE Jr,, Riley MB. 1982. Residues of dibromochloropropane in fresh and preserved peaches. J Agric Food Chem 30:647–649.7119287
*Carter GE Jr., Riley MB. 1984. Dibromochloropropane residues in peaches following fall orchard fumigation. J Agric Food Chem 32:186–187.
*Carter GE Jr., Ligon JT, Riley MB. 1984. DBCP residue studies in soil and well water from two South Carolina peach orchards. Water Air Soil Pollut 22:201–208.
*CAS. 1989. Chemical Abstracts Service CAS on-line registry file. American Chemical Society, Chemical Abstracts Service, Cleveland, OH. December 18,1989.
*Castro CE, Belser NO. 1968. Biodehalogenation. Reductive halogenation of the biocides ethylene dibromide, 1,2-dibromo-3-chloropropane, and 2,3-dibromobutane in soil. Environ Sci Technol 2:779–783.26505514
*CDC. 2018. Fourth national report on human exposure to environmental chemicals, updated tables (March 2018). Centers for Disease Control and Prevention. https://www.cdc.gov/exposurereport/. April 6, 2018.
Chayoth R, Kaplanski J, Sror U, . 1988. The effect of dibromochloropropane (DBCP) on in vitro cyclic AMP levels and testosterone production in rat testes. Andrologia 20:232–237.2845837
Clegg E, Sakai C, Voytek P. 1986. Assessment of reproductive risks. Biol Reprod 34:5–16.3955141
CLPSD. 1989. Contract Laboratory Statistical Database. Viar and Company, Alexandria, VA. July 12, 1989.
*Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
*Cohen D B 1986. Groundwater contamination by toxic substances: A California assessment. American Chemical Society Symp Ser 315:499–529.
*Cohen SZ, Eiden C, Lorber MN. 1986. Monitoring ground water for pesticides. American Chemical Society Symp Ser 315:170–196.
*Cooper ER, Jones AR, Jackson H. 1974. Effects of α-chlorohydrin and related compounds on the reproductive organs and fertility of the male rat. Reprod Fertil 39:379–386.
*Cortes-Gallegos V, Castaneda G, Alonso R, . 1980. Effects of dibromochloropropane upon diurnal variations of gonadotropins and androgens. J Androl 1:277–280.
*Coye MJ, Albrecht WB, Sinks T. 1990. NIOSH health hazard evaluation report no. 81-162, Maui Pineapple Company, Kahuli, Hawaii. HETA 81-162-1935.
*Coye MJ, Albrecht WB, Whorton DM. 1983. NIOSH health hazard evaluation report no. 81-040, Dole Pineapple Corporation, Lanai, Hawaii. HETA 81-0401315.
Crosbie E, Eisenmann C. 1986. Health effects assessment for dibromochloropropane. Prepared by Syracuse Research Corporation, Syracuse, NY for Environmental Criteria and Assessment Office, U.S. Environmental Protection Agency, Cincinnati, OH.
Curry M, Lybarger J, Meyer C. 1979. NIOSH conference on dibromochloropropane. In: Symposium on DBCP, National Institute for Occupational Safety and Health, Division of Surveillance, Hazard Evaluations and Field Studies, Cincinnati, OH, October 19–20, 1977.
*Daft JL. 1988. Rapid determination of fumigant and industrial chemical residues in food. J Assoc Off Anal Chem 71:748–760.3417594
*Daft JL. 1989. Determination of fumigants and related chemicals in fatty and non-fatty foods. J Argic Food Chem 37:560–564.
De Serres F, Malling H, Brockman H, . 1982. Mutagenicity of epichlorohydrin and 1,2-dibromoethane in heterokaryon 12 of Neurospora crassa. Environ Mutagen 4:398–399.
*DOE. 2016a. Table 3: Protective Action Criteria (PAC) Rev. 29 based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. May 2016. Oak Ridge, TN: U.S. Department of Energy. https://sp.eota.energy.gov/pac/teel/Revision_29_Table3.pdf. February 28, 2017.
*DOE. 2016b. Protective Action Criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29 for chemicals of concern - May 2016. Oak Ridge, TN: U.S. Department of Energy. https://energy.gov/ehss/protective-action-criteria-pac-aegls-erpgs-teels-rev-29-chemicals-concern-may-2016. February 28, 2017.
Dohn D, Graziano M, Casida J. 1988. Metabolites of [_3-13_C]1,2-dibromo-3-chloropropane in male rats studied by _13_C and _l_H-_13_C correlated two dimensional NMR spectroscopy. Biochem Pharmacol 37:3485–3495.3421999
Dow Chemical Company. 1978. Exploratory RES Programs with transmittal letter from EPA. Dow Chemical Company, Midland, MI.
Dybing E, Omichinski J, Soderlund E, . 1986. Role of cytochrome P-450 metabolism in 1,2 dibromo-3-chloropropane mutagenicity and nephrotoxicity. Toxicol Lett 31(Suppl):220.
*Eaton M, Schenker M, Whorton M, . 1986. Seven-year follow-up of workers exposed to 1,2-dibromo-3-chloropropane. J Occup Med 28:1145–1150.3097279
*Egnatz D, Ott M G, Townsend J, . 1980. DBCP and testicular effects in chemical workers: An epidemiological survey in Midland, Michigan. J Occup Med 22:727–732.7441391
*Eisenreich.SJ, Looney BB, Thornton JD. 1981. Airborne organic contaminants in the Great Lakes ecosystem. Environ Sci Technol 15:30–38.
*EPA. 1977. U.S. Environmental Protection Agency: Southern Agricultural Insecticides, Inc., et al. Suspension order. Fed Regist 42:57543–57548.
EPA. 1978. Occupational exposure to 1,2-dibromo-3-chloropropane (DBCP). Fed Regist 43:11514–11533.
*EPA. 1979. U.S. Environmental Protection Agency: Dibromochloropropane(DBCP); Suspension order and notice of intent to cancel. Fed Regist 44:65135–65176.
*EPA. 1985a. Drinking water criteria document for 1,2-dibromo-3chloropropane (DBCP). Prepared by Environmental Criteria and Assessment Office, Cincinnati, OH, for Office of Drinking Water, Washington, DC. EACOCIN410. NTIS 118064 PB 86-18.
*EPA. 1985b. U.S. Environmental Protection Agency: Dibromochloropropane; intent to cancel registrations of pesticide products containing dibromochloropropane (DBCP). Fed Regist 50:1122–1123.
*EPA. 1985c. U.S. Environmental Protection Agency: Dibromochloropropane; denial of use of existing stocks. Fed Regist 50:46512.
*EPA. 1985d. Exposure analysis modeling system: Reference manual for EXAMS II. Athens, GA: U.S. Environmental Protection Agency, Environmental Research Lab. EPA600385038.
*EPA. 1985e. U.S. Environmental Protection Agency. List of hazardous substances and reportable quantities. Fed Regist 50:13483.
*EPA. 1986a. Method for the determination of organic compounds in finished drinking water and raw source water. Method Nos. 504.1, 524.1 and 524.2. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Monitoring and Support Laboratory.
*EPA. 1986b. Test method for evaluating solid waste, physical/chemical methods, SW-846, Method Nos. 5030, 8010. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
*EPA. 1987a. List of hazardous substances and reportable quantities. Fed Regist 52:8152.
*EPA. 1987b. Health advisories for 16 pesticides (including alachlor, aldicarb, carbofuran, chlordane, DBCP, 1,2-dichloropropane, 2,4-D, endrin, ethylene dibromide, heptachlor/heptachlor epoxide, lindane, methoxychlor, oxamyl, pentachlorophenol, toxaphene and 2,4,5-TP). Washington, DC: U.S. Environmental Protection Agency, Office of Drinking Water.
EPA. 1987c. List (phase 1) of hazardous constituents for ground-water monitoring. Appendix IX - Ground water monitoring list. Fed Regist 52:25948.
*EPA. 1988a. PC Gems CLOGP3 (Octanol/Water Partition Coefficient). Graphical Exposure Modeling Systems. Washington, DC: U.S. Environmental Protection Agency.
*EPA. 1988b. U.S. Environmental Protection Agency: Discarded chemical products, off-specification species, container residues, and spill residues thereof. Code of Federal Regulations. 40 CFR 261.33.
*EPA. 1988c. U.S. Environmental Protection Agency: Part 268 - Land Disposal Restrictions. Code of Federal Regulations. 40 CFR 261.33(f).
*EPA. 1989a. Interim methods for development of inhalation reference doses. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. EPA600888066F.
EPA. 1989b. Computer printout (CIS): 1977 Non-confidential production data from TSCA inventory. OPTS, CID. Washington, DC: U.S. Environmental Protection Agency.
*EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency, Office of Environmental Information. EPA260B05001.
*EPA. 2009. National primary drinking water regulations. Washington, DC: Office of Ground Water and Drinking Water, U.S. Environmental Protection Agency. EPA816F090004. https://www.epa.gov/sites/production/files/2016-06/documents/npwdr_complete_table.pdf. February 28, 2017.
*EPA. 2012. Drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency, Office of Water. EPA822S12001. https://www.epa.gov/sites/production/files/2015-09/documents/dwstandards2012.pdf. February 28, 2017.
*EPA. 2016. Acute Exposure Guideline Levels (AEGLs) Values. U.S. Environmental Protection Agency. https://www.epa.gov/aegl/access-acute-exposure-guideline-levels-aegls-values#chemicals. February 28, 2017.
*FDA. 2013. Everything added to food in the United States (EAFUS). Washington, DC: U.S. Food and Drug Administration. http://www.accessdata.fda.gov/scripts/fcn/fcnnavigation.cfm?rpt=eafuslisting. February 28, 2017.
*Foote RH, Berndtson WE, Rounsaville TR. 1986a. Use of quantitative testicular histology to assess the effect of dibromochloropropane (DBCP) on reproduction in rabbits. Fundam Appl Toxicol 6:638–647.3710034
*Foote RH, Schermerhorn EC, Simkin ME. 1986b. Measurement of semen quality, fertility, and reproductive hormones to assess dibromochloropropane (DBCP) effects in live rabbits. Fundam Appl Toxicol 6:628–637.3086172
*Fredrickson S, Jackson T, Liao CL, . 1985. Determination of dibromochloropropane and ethylene dibromide in air. IARC Sci Pub1 68:259–268.
FSTRAC. 1988. Summary of state and federal drinking water standards and guidelines. Chemical Communication Subcommittee. Federal-State Toxicology and Regulatory Alliance Committee
*Gabbita KV. 1986. Presence of 1,2-dibromo-3-chloropropane (DBCP) residues in sodium humate and its possible significance. Toxicol Environ Chem 11:203–213.
*Garman JR, Freund T, Lawless EW. 1987. Testing for groundwater contamination at hazardous waste sites. J Chromatogr Sci 251:328–337.
*Generoso W, Cain K, Hughes L. 1985. Tests for dominant-lethal effects of 1,2-dibromo-3chloropropane (DBCP) in male and female mice. Mutat Res 156:103–168.4000172
*George E, Wootton AK, Gatehouse DG. 1990. Micronucleus induction by azobenzene and 1,2-dibromo-3-chloropropane in the rat: Evaluation of a triple-dose protocol. Mutat Res 234(3–4):129–134.2366780
Getzendaner M. 1975. A review of bromine determination in foods. J Assoc Off Anal Chem 58:711–716.1173809
*Ghanayem BI, Maronpot RR, Matthews HB. 1986. Association of chemically induced forestomach cell proliferation and carcinogenesis. Cancer Lett 321:271–278.
*Gingell R, Beatty PW, Mitschke HR, . 1987a. Toxicokinetics of 1,2dibromo-3-chloropropane (DBCP) in the rat. Toxicol Appl Pharmacol 91:386–394.3424372
*Gingell R, Beatty PW, Mitschke HR, . 1987b. Evidence that epichlorohydrin is not a toxic metabolite of 1,2-dibromo-3-chloropropane. Xenobiotica 17:229–240.3564537
*Glass RI, Lyness RN, Mengle DC, , 1979. Sperm count depression in pesticide applicators exposed to dibromochloropropane. Am J Epidemiol 109:346–351.453171
*Goldsmith JR, Potashnik G, Israeli R. 1984. Reproductive outcomes in families of DBCP-exposed men. Arch Environ Health 39:85–89.6721590
*Greenwell A, Tomaxzewski KE, Melnick RL. 1987. A biochemical basis for 1,2-dibromo-3chloropropane-induced male infertility: Inhibition of sperm mitochondrial electron transport activity. Toxicol Appl Pharmacol 91:274–280.3672526
*Hachiya N, Motohashi Y. 2000. Examination of lacZ mutant induction in the liver and testis of Muta^TM^ mouse following injection of halogenated aliphatic hydrocarbons classified as human carcinogens. Ind Health 38:213–220.10812844
*Hahn JD. 1970. Post-testicular anti-fertility effects of epichlorohydrin and 2,3-epoxypropanol. Nature 226:87.
Hamill P, Steinberger E, Levine R, . 1982, The epidemiologic assessment of male reproductive hazard from occupational exposure to TDA and DNT. J Occup Med 24:985–993.6818333
Hawley GG. 1981. The condensed chemical dictionary. 10th ed. New York, NY: Van Nostrand Reinhold Co., 325.
*Hazleton 1977. 104-Week dietary study in rats: 1,2-Dibromo-3-Chloropropane (DBCP). Final report. Unpublished data submitted to Dow Chemical Company. Midland, Michigan. Project No. 174-122.
*Hazleton 1978a. 104-Week dietary study in Rats: 1,2-Dibromo-3-Chloropropane (DBCP): Supplementary histopathology report to final report Dated October 28, 1977. Unpublished data submitted to Dow Chemical Company. Midland, Michigan. Project No. 174-122.
*Hazleton 1978b. 78-Week toxicity and carcinogenicity study in Mice: 1,2-Dibromo-3-Chloropropane, final report. Unpublished data submitted to Dow Chemical Company. Midland, Michigan. Project No. 174-125.
*Hearn S, Ott MG, Kolesar RC, . 1984. Mortality experience of employees with occupational exposure to DBCP. Arch Environ Health 39:49–55.6712284
*Heindel JJ, Berkowitz AS, Kyle G, . 1989. Assessment in rats of the gonadotoxic and hepatorenal toxic potential of dibromochloropropane (DBCP) in drinking water. Fundam Appl Toxicol 13:804–815.2620797
*Ho JSY. 1989. A sequential analysis for volatile organics in water by purge-and-trap capillary column gas chromatography with photoionization and electrolytic conductivity detectors in series. J Chromatogr Sci 27:91–98.
*Hodges LR, Lear B. 1974. Persistence and movement of DBCP in three types of soil. Soil Sci 118:127–130.
*Holme JA, Soderlund EJ, Brunborg G, . 1989. Different mechanisms are involved in DNA damage, bacterial mutagenicity and cytotoxicity induced by 1,2-dibromo-3-chloropropane in suspensions of rat liver cells. Carcinogenesis 10:49–54.2642751
*Holme JA, Soderlund EJ, Brunborg G, . 1991. DNA damage and cell death induced by 1,2dibromo-3-chloropropane (DBCP) and structural analogs in monolayer culture of rat hepatocytes: 3-aminobenzamide inhibits the toxicity of DBCP. Cell Biol Toxicol 7(4):413–432.1794113
Hooper K, Gold L. 1986. Ranking the carcinogenic hazards of occupational exposures: Exposure-Potency Index (EPI) values for nine volatile industrial chemicals. Prog Clin Biol Res 207:217–228.3960874
*HSDB. 1989. Hazardous Substances Data Bank. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
Huff J. 1983. 1,2-dibromo-3-chloropropane. Environ Health Perspect 47:365–369.6825620
IARC. 1977. IARC monographs on the evaluation of the carcinogenic risk of chemicals to man. Some fumigants, the herbicides 2,4-D and 2,4,5-T, chlorinated dibenzodioxins and miscellaneous industrial chemicals. Lyon, France: World Health Organization. Vol 15:83–96.
*IARC. 1979. Monograph on the evaluation of the carcinogenic risk of chemicals to humans. Vol. 20: Some halogenated hydrocarbons. Lyon, France: World Health Organization. Vol 20:l–40, 83–96.
IARC. 1987. IARC monographs on the evaluation of carcinogenic risks to humans. Supplement 7: Overall evaluations of carcinogenicity: An updating of IARC monographs volumes 1 to 42. Lyon, France: World Health Organization. Suppl 7.
*IARC. 1999. 1,2-Dibromo-3-chloropropane. IARC Monographs on the evaluation of carcinogenic risks to humans. Volume 71. Re-evaluation of some organic chemicals, hydrazine and hydrogen peroxide. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Monographs/vol71/mono71-20.pdf. June 29, 2017.
*Inoue TI, Miyazawa T, Tanahashi N, . 1982. Induction of sex-linked recessive lethal mutations in Drosophila melanogaster males by gaseous 1,2-dibromo-3-chloropropane (DBCP). Mutat Res 105:89–94.6811885
Inskeep PB, Guengerich FP. 1984. Glutathione-mediated binding of dibromoalkanes to DNA: Specificity of rat glutathione-S-transferases and dibromoalkane structure. Carcinogenesis 5:805–808.6373044
*IRIS. 1991. Integrated Risk Information System (database). Washington, D.C.: U.S. Environmental Protection Agency.
*IRIS. 2003. 1,2-Dibromo-3-chloropropane (DBCP); CASRN 96-12-8. Chemical assessment summary. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0414_summary.pdf. June 29, 2017.
Irvin T, Sawin V. 1986. Characterization of DNA reaction products formed by in vitro activation of 14^C^-DBCP by microsomes or GSH. Environ Mutagen 8(Suppl6):39.
*Johnston RV, Mensik DC, Taylor HW, . 1986. Single-generation drinking water reproduction study of 1,2-dibromo-3-chloropropane in Sprague-Dawley rats. Bull Environ Contam Toxicol 37:531–537.3768549
*Jones A, Fakhouri G, Gadiel P. 1979. The metabolism of the soil fumigant 1,2-dibromo-3-chloropropane in the rat. Experientia 35:1432–1434.510467
*Jury WA, Winer AM, Spencer WF, . 1987. Transport and transformation of organic chemicals in the soil-air-water ecosystem. Rev Environ Contam Toxicol 99:119–164.
*Kale PG, Baum JW. 1982a. Genetic effects of 1,2-dibromo-3-chloropropane(DBCP) in drosophila. Environ Mutagen 4:681–687.6819134
*Kale PG, Baum JW. 1982b. Genetic effects of strong magnetic fields in Drosophila melanogaster. III. Combined treatment with homogeneous fields and gaseous DBCP. Mutat Res 1051:79–83.
Kapp R. 1979. Evaluation of the genetic toxicity of 1,2-dibromo-3-chloropropane in humans and rats. Diss Abstr Int 40:1516–1660.
Kapp RW, Picciano DJ, Jacobson CB. 1979. Y-chromosomal nondisjunction in dibromochloropropane-exposed workmen. Mutat Res 64:47–51.440325
*Kastl PE, Hermann EA, Braun WH. 1981. Quantitative determination of 1,2-dibromo-3-chloropropane in whole rat blood and drinking water by gas chromatography. J Chromatogr 213:156–161.7287850
*Kato Y, Sato K, Maki S, . 1979a. Metabolic fate of 1,2-dibromo-3chloropropane (DBCP) in rats. J Pestic Sci 4:195–203.
*Kato Y, Matano O, Goto S. 1979b. Covalent binding of DBCP to proteins in vitro. Toxicol Lett 3:299–302.
*Kato Y, Sato K, Harada T, . 1980. Correlation between macromolecular binding of DBCP-metabolite and pathogenicity of necrosis. J Pestic Sci 5:81–88.
*Kawabata A. 1981. Studies on the carcinogenic activity of epichlorohydrin by oral administration in male Wistar rats. J Nara Med Assoc 32:270–280.
Kemper J, Bernstein M. 1978. Dibromochloropropane (DBCP: Final position document). Environmental Protection Agency, Arlington, VA. EPASPRD8020.
*Kloos H. 1983. DBCP pesticide in drinking water wells in Fresno and other communities in the Central Valley of California. Ecol Disease 2:353–367.
*Kluwe WM. 1981. Acute toxicity of 1,2-dibromo-3-chloropropane in F344 male rat. I. Dose-response relationships and differences in routes of exposure. Toxicol Appl Pharmacol 59:71–83.7256759
*Kluwe WM. 1983. Chemical modulation of 1,2-dibromo-3-chloropropanetoxicity. Toxicology 27:287–299.6623477
*Kluwe WM, McNish R, Smithson K, . 1981. Depletion by 1,2-dibromoethane, 1,2-dibromo-3chloropropane, tris(2,3-dibromopropyl)phosphate, and hexachloro-1,3-butadiene of reduced nonprotein sulfhydryl groups in target and non-target organs. Biochem Pharmacol 30:2265–2271.6794573
*Kluwe WM, Greenwell A, Harrington F. 1982. Relationship of tissue nonprotein sulfhydryls to the acute toxic effects of 1,2-dibromo-3-chloropropane. J Pharmacol Exp Ther 220:399–405.7057399
Kluwe WM, Lamb JC IV, Greenwell A, . 1983. 1,2-dibromo-3-chloropropane(DBCP)-induced infertility in male rats mediated by a post-testicular effect. Toxicol Appl Pharmacol 71:294–298.6636194
*Kluwe WM, Weber H, Greenwell A, . 1985. Initial and residual toxicity following acute exposure of developing male rats to dibromochloropropane. Toxicol Appl Pharmacol 79:54–68.4049407
Kodama J, Dunlap M. 1956. Toxicity of 1,2-dibromo-3-chloropropane. Fed Proc 15:448.
*Kouzi SA, Soderlund EJ, Dybing E, . 1995. Comparative toxicity of (+)-(R)- and (−)-(S)-1,2-dibromo-3-chloropropane. Chirality 7(5):359–364. 10.1002/chir.530070509.7495641
*Krishnan K, Anderson ME, Clewell HJ, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
*Kutz FW, Carey AE. 1986. Pesticides and toxic substances in the environment. J Arboric 12:92–95.
*Labaj J, Slamenova D, Lazarova M, . 2007. Induction of DNA-lesions in freshly isolated rat hepatocytes by different genotoxins and their reduction by lignin given either as a dietary component or in in vitro conditions. Nutr Cancer 57(2):209–215. 10.1080/01635580701277643.17571955
*Lag M, Omichinski JG, Dybing E, . 1994. Mutagenic activity of halogenated propanes and propenes: Effect of bromine and chlorine positioning. Chem Biol Interact 93(1):73–84.8069951
*Lag M, Omichinski JG, Soderlund EJ, . 1989a. Role of P-450 activity and glutathione levels in 1,2-dibromo-3-chloropropane tissue distribution, renal necrosis and in vivo DNA damage. Toxicology 56:273–288.2734806
Lag M, Soderlund EJ, Brunborg G, . 1989b. Species differences intesticular necrosis and DNA damage, distribution and metabolism of 1,2-dibromo-3-chloropropane (DBCP). Toxicology 58:133–144.2799822
Lag M, Soderlund E, Omichinski J, . 1989c. Metabolism of selectively methylated and deuterated analogs of 1,2-dibromo-3-chloropropane: Role in organ toxicity and mutagenicity. Chem Biol Interact 69:33–44.2914329
*Lag M, Soderlund EJ, Omichinski JG, . 1991. Effect of bromine and chlorine positioning in the induction of renal and testicular toxicity by halogenated propanes. Chem Res Toxicol 4(5):528–534.1793801
*Lanham J. 1987. Nine-year follow-up of workers exposed to 1,2-dibromo-3chloropropane [letter]. J Occup Med 29:488–490.3112337
*Lantz GD, Cunningham GR, Huckins C, . 1981. Recovery from severe oligospermia after exposure to dibromochloropropane. Fertil Steril 35:46–53.6780379
*Laskin S, Sellakumar AR, Kuschner M, . 1980. Inhalation carcinogenicity of epichlorohydrin in noninbred Sprague-Dawley rats. J Natl Cancer Inst 65:751–757.6932527
*Lee IP, Suzuki K. 1979. Induction of unscheduled DNA synthesis in mouse germ cells following 1,2-dibromo-3-chloropropane (DBCP) exposure. Mutat Res 68:169–173.514303
Legator M, Kapp R Jr. 1984. Detection of chemically induced y-chromosomal nondisjunction in human spermatozoa. Topics in Chemical Mutagenesis 2:265–277.
Leroith D, Potashnik G, Dunn J, . 1981. The exaggerated prolactin response to thyrotropin-releasing hormone and metoclopramide in 1,2-dibromo-3-chloropropane-induced azoospermia. J Clin Endocrinol Metab 52:38–41.6778892
Levine RJ, Symons MJ, Balogh SA, . 1980. A method for monitoring the fertility of workers: 1. Method and pilot studies. J Occup Med 22:781–791.7218054
*Levine RJ, Symons MJ, Balogh SA, . 1981. A method for monitoring the fertility of workers. 2. Validation of the method among workers exposed to dibromochloropropane. J Occup Med 23:183–188.6985522
Levine R, Blunden P, DalCorso R, . 1983. Superiority of reproductive histories to sperm counts in detecting infertility at a dibromochloropropane manufacturing plant. J Occup Med 25:591–597.6886868
*Lipshultz LI, Ross CE, Whorton D, . 1980. Dibromochloropropane and its effects on testicular function in man. J Urol 124:464–468.6775092
Loveday KS, Morris M, Zeiger E. 1986. In-vitro cytogenetic testing using sister chromatid exchange and chromosome aberration end point in CHO cells. Environ Mutagen 8(Suppl 6):48.
*Loveday KS, Lugo MH, Resnick MA, . 1989. Chromosome aberration and sister chromatid exchange tests in Chinese hamster ovary cells in vitro: II. Results with 20 chemicals. Environ Mol Mutagen 13:60–94.2642806
*Lui EMK; Wysocki GP. 1987. Reproductive tract defects induced in adult male rats by postnatal 1,2-dibromo-3-chloropropane exposure. Toxicol Appl Pharmacol 90:299–314.3629605
*MacFarland RT, Gandolfi AT, Sipes IC. 1984. Extra-hepatic GSH-dependent metabolism of 1,2-dibromoethane (DBE) and 1,2-dibromo-3-chloropropane (DBCP) in the rat and mouse. Drug Chem Toxicol 7:213–227.6376058
*Mann JB, Freal JJ, Enos HF, . 1980. Development and application of methodology for determining 1,2-dibromo-3-chloropropane (DBCP) in ambient air. J Environ Sci Health B 15:519–528.7430554
Marsden P, Casida J. 1982. 2-Haloacrylic acids as indicators of mutagenic 2-haloacrolein intermediates in mammalian metabolism of selected promutagens and carcinogens. J Agric Food Chem 30:627–631.6288786
Mayaudon EM. 1978. 1,2-Dibromo-3-chloropropane (DBCP), a nematocide with sterilizing action in humans. Salud Publica de Mexico 5(20):195–200.
*McKee RH, Phillips RD, Traul KA. 1987. The genetic toxicity of 1,2-dibromo-3-chloropropane, 1,2-dibromo-3-chloro-2-methylpropane, and 1,2,3-tribromo-2-methylpropane. Cell Biol Toxicol 3(4):391–406. http://www.ncbi.nlm.nih.gov/pubmed/3333733.3333733
Meyer C. 1984. Critical review of studies relating occupational exposures of males and reproductive capacity. In: Lackey J, Lemasters G, Keye W, ed. Reproduction: The new frontier in occupational and environmental health research. New York, NY: Alan R Liss, Inc., 375–384.
*Milby T, Whorton D. 1980. Epidemiological assessment of occupationally-related, chemically induced sperm count suppression. J Occup Med 22:77–82.7373445
*Milby TH, Whorton HA, Stubbs HA, . 1981. Testicular function among epichlorohydrin workers. Br J Ind Med 38:372–377.6797463
Miller G. 1986. In vitro toxicity of 1,2-dibromo-3-chloropropane to isolated testicular cells. Diss Abstr Int B 47:1007–1128.
Moody D, Smuckler E. 1979. Decrease in hepatic microsomal cytochromes P-450 and b, after treatment with 1,2-dibromo-3-chloropropane (DBCP). Effect on synthesis of protein and heme moieties. Fed Proc 38:845.
Moody D, James J, Clawson G, . 1981. Correlations among the changes in hepatic microsomal components after intoxication with alky halides and other hepatotoxins. Mol Pharmacol 20:685–693.6173739
Moody D, Clawson G, Woo C, . 1982. Cellular distribution of cytochrome P-450 loss in rats of different ages treated with alkyl halides. Toxicol Appl Pharmacol 66:278–289.6761902
*Moody D, Clawson G, Piper W, . 1984. Effects of 1,2-dibromo-3-chloropropane on hepatic heme synthesis. Toxicol Appl Pharmacol 75:561–570.6548049
Moody D, Head B, Woo C, . 1986. NADPH-dependent and -independent loss of cytochrome P-450 in control and phenobarbital-induced rat hepatic microsomes incubated with carbon tetrachloride. Exp Mol Pathol 44:318–328.3720920
Moody D, Clawson G, Geller D, . 1988. Sodium cholate extraction of rat liver nuclear xenobiotic-metabolizing enzymes. Biochem Pharmacol 37:1331–1341.3128299
*Moriya M, Ohta T, Watanabe K, . 1983. Further mutagenicity studies on pesticides in bacterial reversion assay systems. Mutat Res 116:185–216.6339892
*Munnecke DE, VanGundy SD. 1979. Movement of fumigants in soil, dosage responses, and differential effects. Ann Rev Phytopathol 17:405–429.18393685
*NAS/NRC. 1989. Report of the oversight committee. Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press. 15–35.
*NATICH. 1988. NATICH database report on state, local and EPA air toxic activities. National Air Toxics Information Clearinghouse, EPA Office of Air Quality Planning and Standards, Research Triangle Park, NC. 109.
National Research Council. 1986. Drinking water & health. Vol. 6. Board on Toxicology and Environmental Health Hazards, Commission on Life Sciences, National Research Council, 314–236.
*NCI. 1978. Bioassay of dibromochloropropane for possible carcinogenicity. Prepared by Carcinogenesis Program, Division of Cancer Cause & Prevention, National Cancer Institute, Bethesda, MD. NTIS PB277472. NIH 78-828.
*Nelson SJ, lskander M, Volz M, . 1981. Studies of DBCP in subsoils. In: Van Dujvenbooden W, ., eds. Stud Environ Sci 17:169–174.
*Newsome WH, Iverson F, Panopio LG, . 1977. Residues of dibromochloropropane in root crops grown in fumigated soil. J Agric Food Chem 25:684–685.858865
NIOSH. 1978. Criteria document on dibromochloropropane. U.S. Department of Health, Education, and Welfare, Center for Disease Control, National Institute for Occupational Safety and Health, Cincinnati, OH. DHEW publ. no. 78-115.
*NIOSH. 1979. Health hazard evaluation determination report no. 77-126-646. Prepared by Shell Chemical Company, Rocky Mountain Arsenal, Denver, CO for the U.S. Department of Health, Education, and Welfare, Center for Disease Control, National Institute for Occupational Safety and Health, Cincinnati, OH.
*NIOSH. 1985. NIOSH pocket guide to chemical hazards. U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health, Washington, DC. DHHS (NIOSH) publ.no. 85-114, 240–241.
*NIOSH. 1988. Occupational safety and health guideline for dibromochloropropane potential human carcinogen. In: Occupational safety and health guidelines for chemical hazards. U.S. Department of Health, Education, and Welfare, Center for Disease Control, National Institute for Occupational Safety and Health, Cincinnati, OH. Publ. no. 89-104, Suppl. II-OHG, 1–5.
*NIOSH. 1989. National Occupational Exposure Survey (NOES) database. US Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health, Cincinnati, OH. March 29, 1989.
*NIOSH. 1990. NIOSH pocket guide to chemical hazards. U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health, Washington, D.C. DHHS (NIOSH) pub1 no. 90-117, 82–83 and App. A.
*NIOSH. 2016. 1,2-Dibromo-3-chloropropane. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. https://www.cdc.gov/niosh/npg/npgd0184.html. June 29, 2017.
NIOSH/OSHA. 1981. Occupational safety and health guideline for dibromochloropropane: Potential human carcinogen. In: Occupational health guidelines for chemical hazards. U.S. Department of Health, Education, and Welfare, Center for Disease Control, National Institute for Occupational Safety and Health, Cincinnati, OH. DHHS (NIOSH) pub1 no. 81-123.
*NTP. 1982. NTP technical report on the carcinogenesis bioassay of 1,2dibromo-3-chloropropane (CAS no. 96-12-8) in F344 rats and B6C3Fl mice (inhalation study). National Toxicology Program, Research Triangle Park, NC and Bethesda, MD. NTP-81-21.
*NTP. 1985. Fourth annual report on carcinogens. National Toxicology Program, 179–182.
*NTP . 1991. NTP Chemtrack System (database). National Toxicology Program, Division of Toxicology Research and Testing, Central Data Management, Research Triangle Park, NC.
*NTP. 2016. 1,2-Dibromo-3-chloropropane. Report on carcinogens, Fourteenth Edition. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program. https://ntp.niehs.nih.gov/ntp/roc/content/profiles/dibromochloropropane.pdf. June 29, 2017.
*Oakberg E, Cummings C. 1984. Lack of effect of dibromochloropropane on the mouse testis. Environ Mutagen 6:621–625.6468349
*OHM/TADS. 1989. Oral and Hazardous Material Technical Data System. On-line database. Accession No. 7216513. December 12, 1989.
*Ohta T, Nakamura N, Moriya M, . 1984. The SOS-function-inducing activity of chemical mutagens in Escherichia coli. Mutat Res 131:101–109.6201735
*Oki DS, Giambelluca TW. 1987. DBCP, EDB, and TCP contamination of groundwater in Hawaii. Ground Water 25:693–702.
*Olsen GW, Bodner KM, Stafford BA, . 1995. Update of the mortality experience of employees with occupational exposure to 1,2-dibromo-3-chloropropane (DBCP). Am J Ind Med 28(3):399–410.7485193
*Olsen GW, Laham JM, Bodner KM, . 1990. Determinants of spermatogenesis recovery among workers exposed to 1,2-dibromo-3-chloropropane. J Occup Med 32:979–984.2124613
Olson W, Habermann R, Weisburger E, . 1973. Induction of stomach cancer in rats and mice by halogenated aliphatic fumigants. J Natl Cancer Inst 51:1993–1995.4765395
*Omichinski JG, Brunborg G, Soderlund EJ, . 1987. Renal necrosis and DNA damage caused by selectively deuterated and methylated analogs of 1,2dibromo-3-chloropropane in the rat. Toxicol Appl Pharmacol 91:358–370.3424370
*Omichinski JG, Brunborg G, Holme JA, . 1988a. The role of oxidative and conjugative pathways in the activation of 1,2-dibromo-3-chloropropane to DNA-damaging products in rat testicular cells. Mol Pharmacol 34:74–79.3393142
*Omichinski JG, Soderlund EJ, Dybing E, . 1988b. Detection and mechanism of formation of the potent direct-acting mutagen 2-bromoacrolein from 1,2-dibromo-3-chloropropane. Toxicol Appl Pharmacol 92:286–294.3277317
OPD. 1989. OPD chemical buyers directory. 76th ed. New York, NY: Schnell Publishing Co. Inc., 235, 696.
*OSHA. 1988. 1,2-Dibromo-3-chloropropane. Code of Federal Registration. Ch.XVII:940–951.
*OSHA. 2016a. Part 1915 - Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Section 1915.1044 - 1,2-dibromo-3-chloropropane. Occupational Safety and Health Standards. Code of Federal Regulations 29 CFR 1915.1044. https://www.gpo.gov/fdsys/pkg/CFR-2016-title29-vol7/pdf/CFR-2016-title29-vol7-sec1915-1044.pdf. June 29, 2017.
*OSHA. 2016b. Part 1926 - Safety and health regulations for construction. Subpart Z - Toxic and hazardous substances. 1,2-dibromo-3-chloropropane. Occupational Safety and Health Standards. Code of Federal Regulations 29 CFR 1926.1144. https://www.gpo.gov/fdsys/pkg/CFR-2016-title29-vol8/pdf/CFR-2016-title29-vol8-sec1926-1144.pdf. June 29, 2017.
*OSHA. 2016c Subpart Z - Toxic and hazardous substances. 1,2-Dibromo-3-chloropropane. Code of Federal Regulations. Occupational Safety and Health Standards. 29 CFR 1910.1044. https://www.gpo.gov/fdsys/pkg/CFR-2016-title29-vol6/pdf/CFR-2016-title29-vol6-sec1910-1044.pdf. June 29, 2017.
*Overstreet JW, Samuels SJ, Day P, . 1988. Early indicators of male reproductive toxicity. Risk Anal 8:21–26.3287505
*Pellizzari ED, Zweidinger RA, Erickson MD. 1978. Environmental monitoring near industrial sites: Brominated chemicals. Part I. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances, 59, 82, 86, 127,132, 133, 172, 211, 212, 221, 222, 239, 243, 270, 273, 275.
*Pellizzari ED, Zweidinger RA, Sheldon LS. 1985a. GC/MS determination of volatile hydrocarbons in breath samples. In: Fishbein L, O’Neill I, eds. Environmental carcinogens selected methods of analysis. Lyon, France: World Health Organization Vol 7:413–431.
*Pellizzarri ED, Sheldon LS, Bursey JT. 1985b. BC/MS determination of volatile halocarbons in blood and tissue. In: Fishbein L, O’Neill I, eds. Environmental carcinogens selected methods of analysis, Lyon, France: World Health Organization, Vol 7:435–444.
*Peoples SA, Maddy KT, Cusick W, . 1980. A study of samples of well water collected from selected areas in California to determine the presence of DBCP and certain pesticide residues. Bull Environ Contam Toxicol 24:611–618.6892889
*Potashnik G. 1983. A four-year reassessment of workers with dibromochloropropane-induced testicular dysfunction. Andrologia 15:164–170.6407360
*Potashnik G, Abeliovich D. 1985. Chromosomal analysis and health status of children conceived to men during or following dibromochloropropane-induced spermatogenic suppression. Andrologia 17:291–296.4025848
*Potashnik G, Phillip M. 1988. Lack of birth defects among offspring conceived during or after paternal exposure to dibromochloropropane (DBCP). Andrologia 20:90–94.3369712
*Potashnik G, Porath A. 1995. Dibromochloropropane (DBCP): A 17-year reassessment of testicular function and reproductive performance. J Occup Environ Med 37(11):1287–1292.8595498
*Potashnik G, Yanai-Inbar I. 1987. Dibromochloropropane (DBCP): An 8-year re-evaluation of testicular function and reproductive performance. Fertil Steril 47:317–323.3102287
*Potashnik G, Ben-Aderet N, Israeli R, : 1978. Suppressive effect of 1,2-dibromo-3-chloropropane on human spermatogenesis. Fertil Steril 30:444–447.710616
*Potashnik G, Goldsmith J, Insler V. 1984. Dibromochloropropane-induced reduction of the sex-ratio in man. Andrologia 16:213–218.6465547
Powers M, Voelker R, Page N, . 1975. Carcinogenicity of ethylenedibromide (EDB) and 1,2-dibromo-3-chloropropane (DBCP) after oral administration in rats and mice. Toxicol Appl Pharmacol 33:171–172.
Rao K, Murray F, Crawford A, . 1979. Effects of inhaled 1,2-dibromo-3-chloropropane (DBCP) on the semen of rabbits and the fertility of male and female rats. Toxicol Appl Pharmacol 48:A137.
*Rao KS, Burek JD, Murray FJ, . 1982. Toxicologic and reproductive effects of inhaled 1,2-dibromo-3-chloropropane in male rabbits. Fundam Appl Toxicol 2:241–251.6821042
*Rao K, Burek J, Murray F, . 1983. Toxicologic and reproductive effects of inhaled 1,2-dibromo-3-chloropropane in rats. Fundam Appl Toxicol 3:104–110.6873528
Ratpan F, Plaumann H. 1985. Mutagenicity of halogenated three-carbon compounds and their methylated derivatives. (Meeting Abstract). Environ Suppl 3:15.
*Ratpan F, Plaumann H. 1988. Mutagenicity of halogenated propanes and their methylated derivatives. Environ Mol Mutagen 12:253–259.3044786
*Reel JR, Wolkowski-Tyl R, Lawton AD. 1984. Dibromochloropropane: Reproduction and fertility assessment in CD-1 mice when administered by gavage. National Toxicology Program, Research Triangle Park, NC. NTIS PB85118644. NTP 84-263.
*Reznik G, Stinson S, Ward J. 1980a. Respiratory pathology in rats and mice after inhalation of 1,2-dibromo-3-chloropropane or 1,2-dibromoethane for 13weeks. Arch Toxicol 46:233–240.7016076
Reznik G, Reznik-Schuller H, Ward J, . 1980b. Morphology of nasal cavity tumours in rats after chronic inhalation of 1,2-dibromo-3-chloropropane. Br J Cancer 42:772–781.7459212
Reznik G, Stinson S, Ward J. 1980c. Lung tumors induced by chronic inhalation of 1,2-dibromo-3-chloropropane in BCF, mice. Cancer Lett 10:339–342.6253052
*Roldan-Arjona T, Garcia-Pedrajas MD, Luque-Romero FL, . 1991. An association between mutagenicity of the Ara test of Salmonella typhimurium and carcinogenicity in rodents for 16 halogenated aliphatic hydrocarbons. Mutagenesis 6(3):199–206.1881351
Rosenberg M, Feldblum P, Marshall E. 1987. Occupational influences on reproduction: A review of recent literature. J Occup Med 29:584–591.3612335
*Rosenkranz HR. 1975. Genetic activity of 1,2-dibromo-3-chloropropane, a widely-used fumigant. Bull Environ Contam Toxicol 14(1):8–12.1097003
*RTECS. 1984. Registry of Toxic Effects of Chemical Substances. Current Awareness File. U.S. Department of Human Services, Public Health Service, Centers for Disease Control, National Institute of Occupational Safety and Health, Research Triangle Park, NC. March 1984.
*Ruddick JA, Newsome WH. 1979. A teratogenicity and tissue distribution study on dibromochloropropane in the rat. Bull Environ Contam Toxicol 21:483–487.444739
Rush G, Smith J, Newton J, . 1984. Chemically induced nephrotoxicity: Role of metabolic activation. CRC Crit Rev Toxicol 13:99–160.
*Russell LA. 1989. 1,2-dibromo-3-chloropropane (DBCP)-induced nuclear atypia in rat kidney. J Environ Pathol Toxicol Oncol 9:145–157.2732909
*Russell LB, Hunsicker PR, Cacheiro NLA. 1986. Mouse specific-locus test for the induction of heritable gene mutations by dibromochloropropane (DBCP). Mutat Res 170:161–166.3713725
Russell W. 1986. Positive genetic hazard predictions from short-term tests have proved false for results in mammalian spermatogonia with all environmental chemicals so far tested. Prog Clin Biol Res 209B:67–74.3092243
*Ruth JH. 1986. Odor thresholds and irritation levels of several chemical substances: A review. Am Ind Hyg Assoc J 47:A-142–A151.3706135
*Ryu JC, Kim YJ, Chai YG. 2002. Mutation spectrum of 1,2-dibromo-3-chloropropane, an endocrine disruptor, in the lacI transgenic Big Blue Rat2 fibroblast cell line. Mutagenesis 17(4):301–307.12110625
*Sabljic A. 1984. Predictions of the nature and strength of soil sorption of organic pollutants by molecular topology. J Agric Food Chem 32:243–246.
*Saegusa J. 1986. Radiomimetic toxicity of 1,2-dibromo-3-chloropropane (DBCP). Ind Health 24:1–14.3710834
Saegusa J. 1987. Age-related susceptibility to dibromochloropropane. Toxicol Lett 36:45–50.3564068
*Saegusa J, Hasegawa H, Kawai K. 1982. Toxicity of 1,2-dibromo-3-chloropropane (DBCP): I. Histopathological examination of male rats exposed to DBCP vapour. Ind Health 20:315–323.7153065
*Saito-Suzuki R, Teramoto S, Shirasu Y. 1982. Dominant lethal study in rats with 1,2-dibromo-3-chloropropane and its structurally related compounds. Mutat Res 101:321–327.7110159
*Sandifer S, Wilkins R, Loadhold C, . 1979. Spermatogenesis in agricultural workers exposed to dibromochloropropane (DBCP). Bull Environ Toxicol 23:703–710.
*Sasaki YF, Imanishi H, Watanabe M, . 1986. Mutagenicity of 1,2-dibromo-3-chloropropane (DBCP) in the mouse spot test. Mutat Res 174:145–147.3713732
*Sasaki YF, Saga A, Akasaka M, . 1998. Detection of in vivo genotoxicity of haloalkanes and haloalkenes carcinogenic to rodents by the alkaline single cell gel electrophoresis (comet) assay in multiple mouse organs. Mutat Res 419(1–3):13–20.9804871
*Sax NI, Lewis RJ. 1987. Hawley’s condensed chemical dictionary. 10th ed. New York, NY: Van Nostrand Reinhold Co., 367.
*Scharnweber HC. 1979. The Dow Experience. In: Proceedings of the October 19-20, 1977 NIOSH conference on dibromochloropropane, Cincinnati, OH, 30–38.
*Schenker MB, Samuels SJ, Perkins C, . 1988. Prospective surveillance of semen quality in the workplace. J Occup Med 30:336–344.3379487
Schneiderman M. 1987. Mortality experience of employees with occupational exposure to DBCP [letter]. Arch Environ Health 42:245–247.3662613
Schrag S, Dixon R. 1985. Occupational exposures associated with male reproductive dysfunction. Ann Rev Pharmacol Toxicol 25:567–592.2408559
Sever L, Hess01 N. 1985. Toxic effects of occupational and environmental chemicals on the testes. In: Thomas J, Korach K, McLachlan J, ed. Endocrine toxicology. New York, NY: Raven Press, 211–248.
*Shaked I, Sod-Moriah UA, Kaplanski J, . 1988. Reproductive performance of dibromochloropropane-treated female rats. Int J Fertil 331:129–133.
*Shelby MD, Witt KL. 1995. Comparison of results from mouse bone marrow chromosome aberration and micronucleus tests. Environ Mol Mutagen 25(4):302–313.7607185
*Shelby MD, Erexson GL, Hook GJ, . 1993. Evaluation of a three-exposure mouse bone marrow micronucleus protocol: Results with 49 chemicals. Environ Mol Mutagen 21(2):160–179.8444144
*Shemi D, Sod-Moriah UA, Kaplanski J, . 1987. Gonadotoxicity and kinetics of dibromochloropropane in male rats. Toxicol Lett 36:209–212.3590216
Shiau S, Huff R, Wells B, . 1980. Mutagenicity and DNA-damaging activity for several pesticides tested with bacillus subtilis mutants. Mutat Res 71:169–179.6771645
Shirasu Y, Moriya M, Tezuka H, . 1984. Mutagenicity of pesticides. Environ Sci Res 31:617–624.
*Silverstein RM, Bassler GC, Morrill TC. 1974. Spectrometric identification of organic compounds. 3rd ed. New York, NY: John Wiley & Sons, 239.
*Simula TP, Glancey MJ, Soderlund EJ, . 1993. Increased mutagenicity of 1,2-dibromo-3-chloropropane and tris(2,3-dibromopropyl)phosphate in Salmonella TA100 expressing human glutathione S-transferases. Carcinogenesis 14(11):2303–2307.8242859
*Slutsky M, Levin JL, Levy BS. 1999. Azoospermia and oligospermia among a large cohort of DBCP applicators in 12 countries. Int J Occup Environ Health 5(2):116–122. 10.1179/oeh.1999.5.2.116.10330512
*Soderlund EJ, Brunborg G, Holme JA, . 1991. Co-culture systems for assessing the stability and genotoxicity of reactive 1,2-dibromo-3-chloropropane (DBCP) metabolites. Mutagenesis 6(1):25–30.2038269
*Soderlund EJ, Brunborg G, Omichinski JA, . 1988. Testicular necrosis and DNA damage caused by deuterated and methylated analogs of 1;2-dibromo-3-chloropropane in the rat. Toxicol Appl Pharmacol 94:437–447.3400095
*Soderlund EJ, Lag M, Holme JA, . 1990. Species differences in kidney necrosis and DNA damage, distribution and glutathione-dependent metabolism of 1,2-dibromo-3-chloropropane (DBCP). Pharmacol Toxicol 66(4):287–293.2371234
Sod-Moriah UA, Sror U, Shemi D, . 1988. Long term effects of dibromochloropropane (DBCP) on male rats’ reproductive system. Andrologia 20:60–66.3130764
Starr T, Dalcorso R, Levine R. 1986. Fertility of workers. A comparison of logistic regression and indirect standardization. Am J Epidemiol 123:490–498.3946395
*State of Kentucky. 1986. New or modified sources emitting toxic air pollutants. Natural Resources and Environmental Protection, Cabinet, Department for Environmental Protection, Division of Air Pollution (Proposed Regulation).
Steeno O, Pangkahila A. 1984. Occupational influences on male fertility and sexuality. Andrologia 16:5–22.6372552
Stellman J. 1986. Environmental agents and birth outcomes. Ann NY Acad Sci 477:116–122.3545013
*Stenger VA. 1978. Bromine compounds. In: Kirk-Othmer encyclopedia of chemical technology, 3rd. ed. New York, NY: Wiley-Interscience, 243–263.
*Stolzenberg SJ, Hine CH. 1979. Mutagenicity of halogenated and oxygenated three-carbon compounds. J Toxicol Environ Health 5:1149–1158.393836
STORET. 1989. STORET database. U.S. Environmental Protection Agency, Washington, DC. December 14, 1989.
*Stutz DR, Janusz SJ. 1988. Hazardous materials injuries: A handbook for pre-hospital care. 2nd ed. Beltsville, Maryland: Bradford Communications Corporation, 300–301.
*Suzuki K, Lee I. 1981. Induction of aryl hydrocarbon hydroxylase and epoxide hydrolase in rat liver, kidney, testis, prostate glands, and stomach by a potent nematocide, 1,2-dibromo-3-chloropropane. Toxicol Appl Pharmacol 58:151–155.7233434
*Swann RL, Laskowski DA, McCall PJ, . 1983. A rapid method for the estimation of the environmental parameters of octanol/water partition coefficient, soil sorption constant, water to air ratio, and water solubility. Res Rev 85:17–28.
*Takahashi W, Wong L, Rogers B, . 1981. Depression of sperm counts among agricultural workers exposed to dibromochloropropane and ethylenedibromide. Bull Environ Contam Toxicol 27:551–558.7030435
Teramoto S, Shirasu Y. 1989. Genetic toxicology of 1,2-dibromo-3-chloropropane(DBCP). Mutat Res 221:1–9.2664492
*Teramoto S, Saito R, Aoyama H, . 1980. Dominant lethal mutation induced in male rats by 1,2-dibromo-3-chloropropane (DBCP). Mutat Res 77:71–78.6987512
*Tezuka H, Ando N, Suzuki R, . 1980. Sister-chromatid exchanges and chromosomal aberrations in cultured Chinese hamster cells treated with pesticides positive in microbial reversion assays. Mutat Res 78:177–191.7393245
*Thomas RG. 1982. Volatilization from water. In: Lyman WJ, Reehl WF, Rosenblatt DH, eds. Handbook of chemical property estimation methods. New York, NY: McGraw-Hill Book Co., 4–9; 5–5; 15–9 to 15–31.
*Tofilon PJ, Clement RP, Piper WN. 1980. Inhibition of the biosynthesis of rat testicular heme by 1,2-dibromo-3-chloropropane. Biochem Pharmacol 29:2563–2566.6775638
Tofilon P. 1981. Investigations into the regulation of rat testicular heme synthesis. Diss Abstr Int 42/08-B:3223–3304.
*Tonogai Y, Ito Y, Ogawa S, . 1986. Determination of dibromochloropropane and related fumigants in citrus fruit. J Food Prot 49:909–913.30965502
Torkelson TR, Rowe VK. 1981. Halogenated aliphatic hydrocarbons: 1,2-dibromo-3-chloropropane. In: Clayton GD, Clayton FE, eds. Patty’s industrial hygiene and toxicology, Vol. 2B, 3rd ed. New York, NY: John Wiley& Sons.
*Torkelson TR, Sadek SE, Rowe VK. 1961. Toxicologic investigations of 1,2-dibromo-3-chloropropane. Toxicol Appl Pharmacol 3:545–559.13777510
Traul K, McKee R, Phillips R. 1985. The genetic toxicity of 1,2-dibromo-3-chloropropane, 1,2-dibromo-3-chloro-2-methylpropane, and 1,2,3-tribromo-2-methylpropane (Meeting Abstract). Environ Mutagen 7(Suppl 3):17–18.3979352
*TRI16. 2017. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Office of Information Analysis and Access. Office of Environmental Information. U.S. Environmental Protection Agency. Toxics Release Inventory. http://www.epa.gov/triexplorer/. November 10, 2017.
Tsongas T, Infante P. 1984. Occupational reproductive hazards: Regulatory concerns. Prog Clin Biol Res 160:533–539.6473477
*Tuazon EC, Atkinson R, Aschmann SM, . 1986. Atmospheric loss processes of 1,2-dibromo-3-chloropropane and trimethyl phosphate. Environ Sci Technol 20:1043–1046.22257406
*Van Duuren BI, Goldschmidt BM, Loewengart G, . 1979. Carcinogenicity of halogenated olefinic and aliphatic hydrocarbons in mice. J Natl Cancer Inst 63:1433–1439.292813
*Verschueren K, ed. 1983. Handbook of environmental data on organic chemicals. New York, NY: Van Nostrand Reinhold Co., 464–465.
*View. 1990. On-line database. Atlanta, GA: Agency for Toxic Substances and Disease Registry (ATSDR), Office of External Affairs, Exposure and Disease Registry Branch. November 8, 1989.
*Wallace LA, Pellizzari ED, Hartwell TD, . 1986. Total Exposure Assessment Methodology (TEAM) study: Personal exposures. Indoor-outdoor relationships, and breath levels of volatile organic compounds in New Jersey. Environ Int 12:369–387.
*Warren DW, Wisner JR, Ahmad N. 1984. Effects of 1,2-dibromo-3-chloropropane on male reproductive function in the rat. Biol Reprod 31:454–463.6487690
Warren DW, Ahmad N. 1986. Effect of maternal administration of 1,2-dibromo-3-chloropropane on fetal testosterone production and adult sexual behavior of male offspring. J Androl 7:20.
*Warren DW, Ahmad N, Rudeen P. 1988. The effects of fetal exposure to 1,2-dibromo-3-chloropropane on adult male reproductive function. Biol Reprod 39:707–716.3196801
Weisburger E. 1977. Carcinogenicity studies on halogenated hydrocarbons. Environ Health Perspect 21:7–16.206428
*Westrick JJ, Mello JW, Thomas RF. 1984. The groundwater supply survey. J Am Water Works Assoc 76:52–59.
*WHO. 2010. Guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. January 08, 2014.
*WHO. 2017. Guidelines for drinking-water quality. Fourth edition incorporating the first addendum. Geneva, Switzerland: World Health Organization. http://apps.who.int/iris/bitstream/10665/254637/1/9789241549950-eng.pdf?ua=1. February 28, 2017.
*Whorton M, Foliart D. 1983. Mutagenicity, carcinogenicity and reproductive effects of dibromochloropropane (DBCP). Mutat Res 123:13–30.6888412
*Whorton D, Krauss RM. Marshall S, . 1977. Infertility in male pesticide workers. Lancet 2:1259–1261.73955
*Whorton MD, Milby TH, Krauss RM, . 1979. Testicular function in DBCP exposed pesticide workers. J Occup Med 21:161–166.556420
Whorton M, Morgan R, Wong O, . 1988. Problems associated with collecting drinking water quality data for community studies: A case example, Fresno County, California. Am J Public Health 78:46–51.
*Whorton MD, Wong O, Morgan RW, . 1989. An epidemiologic investigation of birth outcomes in relation to dibromochloropropane contamination in drinking water in Fresno County, California, USA. Int Arch Occup Environ Health 61:403–407.2744871
*Wiger R, Holme JA, Hongslo JK, . 1998. Single-strand breaks, cell cycle arrest and apoptosis in HL-60 and LLCPK_1_ cells exposed to 1,2-dibromo-3-chloropropane. Cell Biol Toxicol 14(4):267–282.9733282
Wilbur S, Gray DA, Durkin P. 1984. Preliminary draft: External review draft of drinking water criteria documents on 1,2-dibromo-3-chloropropane. Prepared by Syracuse Research Corporation, Syracuse, NY for Environmental Criteria and Assessment Office, U.S. EPA, Cincinnati, OH.
Wills J. 1983. Dibromochloropropane. Encyclopedia of occupational health and safety, Vol. 1, 621–623.
*Wilson JT, Enfield CG, Dunlap WJ, . 1981. Transport and fate of selected organic pollutants in a sandy soil. J Environ Qual 10:501–506.
*Windholz M, ed. 1983. The Merck index. 10th ed. Rahway, NJ: Merck and Co., Inc., 438.
*Wong O, Brocker W, Davis HV, . 1984. Mortality of workers potentially exposed to organic and inorganic brominated chemicals, DBCP, TRIS, PBB, and DDT. Br J Ind Med 41:15–24.6318800
*Wong O, Whorton MD, Gordon N, . 1988. An epidemiologic investigation of the relationship between DBCP contamination in drinking water and birthrates in Fresno County, California. Am J Public Health 78:43–46.3337304
*Wong O, Morgan RW, Whorton MD, . 1989. Ecological analyses and case control studies of gastric cancer and leukemia in relation to DBCP in drinking water in Fresno County, California. Br J Ind Med 46:521–528.2775672
*Yoon J, Mason J, Valencia R, . 1985. Chemical mutagenesis testing in drosophila. IV. Results of 45 coded compounds tested for the National Toxicology Program. Environ Mutagen 7:349–367.3930235
*Zimmering S. 1983. 1,2-dibromo-3-chloropropane (DBCP) is positive for sex linked recessive lethals, heritable translocations and chromosome loss in drosophila. Mutat Res 119:287–288.6828063