# VERSION HISTORY

Date | Description
April 2018 | Update of data in Chapters 2, 3, and 7
September 1992 | Final Toxicological profile released