# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding 1,2-dibromo-3-chloropropane in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for 1,2-dibromo-3-chloropropane.

Table 7-1 Regulations and Guidelines Applicable to 1,2-Dibromo-3-Chloropropane

Agency | Description | Information | Reference
Air
EPA | RfC | 2x10^-4^ mg/m^3a^ | IRIS 2003
WHO | Air quality guidelines | No data | WHO 2010
Water & Food
EPA | Drinking water health advisories | | EPA 2012
EPA | 1-Day (10 kg child) | 0.2 mg/L | EPA 2012
EPA | 10-Day (10 kg child) | 0.05 mg/L | EPA 2012
EPA | mg/L at 10^-4^ cancer risk | 0.003 | EPA 2012
EPA | National primary drinking water regulations | | EPA 2009
EPA | MCL | 0.0002 mg/L^b^ | EPA 2009
EPA | Public health goal | Zero | EPA 2009
EPA | RfD | No data | IRIS 2003
WHO | Drinking water quality guidelines | | WHO 2017
WHO | Guideline value | 0.001 mg/L (1 μg/L)^c^ | WHO 2017
FDA | EAFUS | No data^d^ | FDA 2013
Cancer
HHS | Carcinogenicity classification | Reasonably anticipated to be a human carcinogen^e^ | NTP 2016
EPA | Carcinogenicity classification | Not evaluated | IRIS 2003
IARC | Carcinogenicity classification | Group 2B^f,g^ | IARC 1999
Occupational
OSHA | PEL (8-hour TWA) for occupational exposure | 1 ppb^h^ | OSHA 2016a, 2016b, 2016c
NIOSH | REL (up to 10-hour TWA) | No data | NIOSH 2016
Emergency Criteria
EPA | AEGLs-air | No data | EPA 2016
DOE | PACs-air | | DOE 2016a
DOE | PAC-1^i^ | 0.003 ppm | DOE 2016a
DOE | PAC-2^i^ | 2.2 ppm | DOE 2016a
DOE | PAC-3^i^ | 4.3 ppm | DOE 2016a

a Based on testicular effects found in a 13-week subchronic rabbit inhalation study.

b Potential health effects from long-term exposure above the MCL: reproductive difficulties; increased risk of cancer.

c Derivation based on a linearized multistage model applied to the data on the incidence of stomach, kidney, and liver tumors in the male rat in a 104-week dietary study. Guideline value should be protective for reproductive toxicity.

d The EAFUS list of substances contains ingredients added directly to food that FDA has either approved as food additives or listed or affirmed as GRAS.

e Based on sufficient evidence of carcinogenicity from studies in experimental animals.

f Group 2B: Possibly carcinogenic to humans.

g Based on sufficient evidence for carcinogenicity in experimental animals and inadequate evidence in humans.

h Employer shall ensure no employee is exposed to eye or skin contact with dibromochloropropane.

i Definitions of PAC terminology are available from the U.S. Department of Energy (DOE 2016b).

AEGL = acute exposure guideline levels; AIHA = American Industrial Hygiene Association; DOE = Department of Energy; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; ERPG = emergency response planning guidelines; FDA = Food and Drug Administration; GRAS = generally recognized as safe; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; IRIS = Integrated Risk Information System; MCL = maximum contaminant level; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = Protective Action Criteria; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TLV = threshold limit values; TWA = time-weighted average; WHO = World Health Organization