# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Data pertaining to the chemical identity of 1,2-dibromo-3-chloropropane are listed in Table 4-1.

Table 4-1 Chemical Identity of 1,2-Dibromo-3-Chloropropane

Characteristic | Information | Reference
Chemical name | 1,2-Dibromo-3-chloropropane | CAS 1989
Synonym(s) and registered trade name(s) | Nemagon; Nemafume; Fumazone; Fumagon; Nemabrom; Nemazon; OS 1897; and others | OHM/TADS 1989
Chemical formula | C_3_H_5_Br_2_Cl | CAS 1989
Chemical structure | Figure showing the chemical structure of 1,2,-dibromo-3-chloropropane | CAS 1989
CAS Registry Number | 96-12-8 | CAS 1989

CAS = Chemical Abstracts Service

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

The physical and chemical properties of 1,2-dibromo-3-chloropropane are presented in Table 4-2.

Table 4-2 Physical and Chemical Properties of 1,2-Dibromo-3-Chloropropane

Property | Information | Reference
Molecular weight | 236.36 | Windholz 1983
Color | Colorless (when pure); amber to dark brown, yellow (technical grade) | NIOSH 1985; Sax and Lewis 1987; Verschueren 1983
Physical state | Liquid | Windholz 1983
Melting point | 6°C | Stenger 1978
Boiling point | 196°C | Windholz 1983
Density at 20°C | 2.093 g/cm^3^ | Windholz 1983
Odor | Pungent | Windholz 1983
Odor threshold:
Water | No data
Air | 0.0965 mg/m^3^ | Ruth 1986
Solubility:
Water at 20°C | 1,230 mg/L | Munnecke and VanGundy 1979
Organic solvents | Miscible with methanol, ethanol, isopropyl alcohol, hydrocarbons, halogenated hydrocarbons, and oils | Windholz 1983
Partition coefficients:
Log K_ow_ | 2.26 (estimated) | EPA 1988a
Log K_oc_ | 2.17; 2.11 | Sabljic 1984; Wilson et al. 1981
Vapor pressure at 20°C | 0.58 mmHg | Munnecke and VanGundy 1979
Henry’s law constant at 25°C | 1.47x10^-4^ atm-m^3^/mol^a^ | Thomas 1982
Autoignition temperature | No data
Flashpoint | 76.6°C (open cup) | Sax and Lewis 1987
Flammability limits | No data
Conversion factors | 1 ppm=9.67 mg/m^3^
Explosive limits | No data

a Calculated from vapor pressure and water solubility using equation 15-8 in Lyman et al. (1982).