# APPENDIX B LITERATURE SEARCH FRAMEWORK FOR 1,2-DIBROMO-3-CHLOROPROPANE

The objective of the toxicological profile is to evaluate the potential for human exposure and the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to 1,2-dibromo-3-chloropropane.

## B.1 LITERATURE SEARCH AND SCREEN

A literature search and screen was conducted to identify studies examining health effects, toxicokinetics, mechanisms of action, susceptible populations, biomarkers, and chemical interactions data for 1,2-dibromo-3-chloropropane. ATSDR primarily focused on peer-reviewed articles without publication date or language restrictions. Non-peer-reviewed studies that were considered relevant to the assessment of the health effects of 1,2-dibromo-3-chloropropane have undergone peer review by at least three ATSDR-selected experts who have been screened for conflict of interest. The inclusion criteria used to identify relevant studies examining the health effects of 1,2-dibromo-3-chloropropane are presented in Table B-1.

Table B-1 Inclusion Criteria for the Literature Search and Screen

- Health Effects; - Species; - Human; - Laboratory mammals; - Route of exposure; - Inhalation; - Oral; - Dermal (or ocular); - Parenteral (these studies will be considered supporting data); - Health outcome; - Death; - Systemic effects; - Body weight effects; - Respiratory effects; - Cardiovascular effects; - Gastrointestinal effects; - Hematological effects; - Musculoskeletal effects; - Hepatic effects; - Renal effects; - Dermal effects; - Ocular effects; - Endocrine effects; - Immunological effects; - Neurological effects; - Reproductive effects; - Developmental effects; - Other noncancer effects; - Cancer
- Toxicokinetics; - Absorption; - Distribution; - Metabolism; - Excretion; - PBPK models; - Biomarkers; - Biomarkers of exposure; - Biomarkers of effect; - Interactions with other chemicals

### B.1.1 Literature Search

The current literature search was intended to update the health effects sections of the existing toxicological profile for 1,2-dibromo-3-chloropropane (ATSDR 1992), thus, the literature search was restricted to studies published between January 1990 to March 2017. The following main databases were searched in March 2017:

- PubMed
- National Library of Medicine’s TOXLINE
- Scientific and Technical Information Network’s TOXCENTER

The search strategy used the chemical names, Chemical Abstracts Service (CAS) numbers, synonyms, and Medical Subject Headings (MeSH) terms for 1,2-dibromo-3-chloropropane. The query strings used for the literature search are presented in Table B-2.

The search was augmented by searching the Toxic Substances Control Act Test Submissions (TSCATS), NTP website, and National Institute of Health Research Portfolio Online Reporting Tools Expenditures and Results (NIH RePORTER) databases using the queries presented in Table B-3. Additional databases were searched in the creation of various tables and figures, such as the TRI Explorer, the Substance priority list (SPL) resource page, and other items as needed. Regulations applicable to 1,2-dibromo-3-chloropropane were identified by searching international and U.S. agency websites and documents.

Review articles were identified and used for the purpose of providing background information and identifying additional references. ATSDR also identified reports from the grey literature, which included unpublished research reports, technical reports from government agencies, conference proceedings and abstracts, and theses and dissertations.

Table B-2 Database Query Strings

Database search date | Query string
PubMed
03/2017 | ((96-12-8[rn] OR 67708-83-2[rn] OR 96K0FD4803[rn] OR “1,2-dibromo-3-chloropropane”[supplementary concept] OR “1,2-dibromo-3-chloropropane”[nm]) AND (1990/01/01 : 3000[dp] OR 1990/01/01 : 3000[mhda])) OR (((“1,2-Dibrom-3-chlor-propan”[tw] OR “1,2-Dibromo-3-chloropropane”[tw] OR “1,2-Dibromo-3-cloro-propano”[tw] OR “1,2-Dibromochloropropane”[tw] OR “1,2-Dibroom-3-chloorpropaan”[tw] OR “1-Chloro-2,3-dibromopropane”[tw] OR “2,3-Dibromo-1-chloropropane”[tw] OR “3-Chloro-1,2-dibromopropane”[tw] OR “BBC 12”[tw] OR “Dibromchlorpropan”[tw] OR “Dibromochloropropane”[tw] OR “Durham Nematicode EM 17.1”[tw] OR “Fumagon”[tw] OR “Fumazon 86”[tw] OR “Fumazone”[tw] OR “Fumazone 86”[tw] OR “Fumazone 86E”[tw] OR “Gro-Tone Nematode Granular”[tw] OR “Nemabrom”[tw] OR “Nemafume”[tw] OR “Nemagon”[tw] OR “Nemagone”[tw] OR “Nemanax”[tw] OR “Nemanex”[tw] OR “Nemapaz”[tw] OR “Nemaset”[tw] OR “Nematocide EM 12.1”[tw] OR “Nematocide EM 15.1”[tw] OR “Nematocide Solution EM 17.1”[tw] OR “Nematox”[tw] OR “Nemazon”[tw] OR “Oxy DBCP”[tw]) NOT medline[sb]) AND (1990/01/01 : 3000[dp] OR 1990/01/01 : 3000[crdat] OR 1990/01/01 : 3000[edat]))
Toxline
03/2017 | ( “1 2-dibrom-3-chlor-propan” OR “1 2-dibromo-3-chloropropane” OR “1 2-dibromo-3-cloro-propano” OR “1 2-dibromochloropropane” OR “1 2-dibroom-3-chloorpropaan” OR “1-chloro-2 3-dibromopropane” OR “2 3-dibromo-1-chloropropane” OR “3-chloro-1 2-dibromopropane” OR “bbc 12” OR “dibromchlorpropan” OR “dibromochloropropane” OR “durham nematicode em 17 1” OR “fumagon” OR “fumazon 86” OR “fumazone” OR “fumazone 86” OR “fumazone 86e” OR “gro-tone nematode granular” OR “nemabrom” OR “nemafume” OR “nemagon” OR “nemagone” OR “nemanax” OR “nemanex” OR “nemapaz” OR “nemaset” OR “nematocide em 12 1” OR “nematocide em 15 1” OR “nematocide solution em 17 1” OR “nematox” OR “nemazon” OR “oxy dbcp” OR 96-12-8 [rn] OR 67708-83-2 [rn] ) AND 1990:2017 [yr] AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) AND NOT PubMed [org] AND NOT pubdart [org]
Toxcenter
03/2017 | FILE ‘TOXCENTER’ ENTERED AT 09:06:42 ON 23 MAR 2017; L1 2132 SEA 96-12-8; L2 11 SEA 67708-83-2; L3 2141 SEA L1 OR L2; L4 2113 SEA L3 NOT TSCATS/FS; L5 2029 SEA L4 NOT PATENT/DT; L6 781 SEA L5 AND PY>=1990; ACTIVATE TOXQUERY/Q; -------; L7 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?); L8 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST,CT, IT); L9 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50); L10 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT; L11 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?); L12 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?); L13 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS OR; DIETARY OR DRINKING(W)WATER?); L14 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE)); L15 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?); L16 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM?; OR; OVUM?); L17 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?); L18 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?); L19 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? OR; SPERMATOB? OR SPERMATOC? OR SPERMATOG?); L20 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR; SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?); L21 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?); L22 QUE (ENDOCRIN? AND DISRUPT?); L23 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?); L24 QUE (WEAN? OR OFFSPRING OR AGE(W)FACTOR?); L25 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?); L26 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER? OR; NEOPLAS?); L27 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?); L28 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?); L29 QUE (NEPHROTOX? OR HEPATOTOX?); L30 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?); L31 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?); L32 QUE L7 OR L8 OR L9 OR L10 OR L11 OR L12 OR L13 OR L14 OR L15 OR L16 OR L17 OR L18 OR L19 OR L20 OR L21 OR L22 OR L23 OR L24 OR L25 OR L26 OR L27 OR L28 OR L29 OR L30 OR L31; L33 QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR MURIDAE; OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR SWINE; OR PORCINE OR MONKEY? OR MACAQUE?); L34 QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR LAGOMORPHA; OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE); L35 QUE L32 OR L33 OR L34; L36 QUE (NONHUMAN MAMMALS)/ORGN; L37 QUE L35 OR L36; L38 QUE (HUMAN OR HUMANS OR HOMINIDAE OR MAMMALS OR MAMMAL? OR; PRIMATES OR PRIMATE?); L39 QUE L37 OR L38; -------; L40 595 SEA L6 AND L39; L41 83 SEA L40 AND MEDLINE/FS; L42 97 SEA L40 AND BIOSIS/FS; L43 332 SEA L40 AND CAPLUS/FS; L44 83 SEA L40 NOT (MEDLINE/FS OR BIOSIS/FS OR CAPLUS/FS); L45 469 DUP REM L41 L42 L44 L43 (126 DUPLICATES REMOVED); L*** DEL 83 S L40 AND MEDLINE/FS; L*** DEL 83 S L40 AND MEDLINE/FS; L46 83 SEA L45; L*** DEL 97 S L40 AND BIOSIS/FS; L*** DEL 97 S L40 AND BIOSIS/FS; L47 53 SEA L45; L*** DEL 332 S L40 AND CAPLUS/FS; L*** DEL 332 S L40 AND CAPLUS/FS; L48 267 SEA L45; L*** DEL 83 S L40 NOT (MEDLINE/FS OR BIOSIS/FS OR CAPLUS/FS); L*** DEL 83 S L40 NOT (MEDLINE/FS OR BIOSIS/FS OR CAPLUS/FS); L49 66 SEA L45; L50 386 SEA (L46 OR L47 OR L48 OR L49) NOT MEDLINE/FS D SCAN L50

Table B-3 Strategies to Augment the Literature Search

Source | Query and number screened when available
TSCATS ^a^
03/2017 | Compounds searched: 96-12-8, 67708-83-2
NTP
03/2017 | 96-12-8; 67708-83-2; 1,2-Dibromo-3-chloropropane; 1,2-Dibromochloropropane; 1-Chloro-2,3-dibromopropane; 2,3-Dibromo-1-chloropropane; 3-Chloro-1,2-dibromopropane; Dibromochloropropane
NIH RePORTER
06/2017 | Text Search: “1,2-Dibrom-3-chlor-propan” OR “1,2-Dibromo-3-chloropropane” OR “1,2-Dibromo-3-cloro-propano” OR “1,2-Dibromochloropropane” OR “1,2-Dibroom-3-chloorpropaan” OR “1-Chloro-2,3-dibromopropane” OR “2,3-Dibromo-1-chloropropane” OR “3-Chloro-1,2-dibromopropane” OR “BBC 12” OR “Dibromchlorpropan” OR “Dibromochloropropane” OR “Durham Nematicode EM 17.1” OR “Fumagon” OR “Fumazon 86” OR “Fumazone” OR “Fumazone 86” OR “Fumazone 86E” OR “Gro-Tone Nematode Granular” OR “Nemabrom” OR “Nemafume” OR “Nemagon” OR “Nemagon 20” OR “Nemagon 206” OR “Nemagon 20G” OR “Nemagon 90” OR “Nemagon soil fumigant” OR “Nemagone” OR “Nemanax” OR “Nemanex” OR “Nemapaz” OR “Nemaset” OR “Nematocide EM 12.1” OR “Nematocide EM 15.1” OR“Nematocide Solution EM 17.1” OR “Nematox” (Advanced), Search in: Projects Admin IC: All, Fiscal Year: Active Projects
Other | Identified throughout the assessment process

a Several versions of the TSCATS database were searched, as needed, by CASRN including TSCATS1 via Toxline (no date limit), TSCATS2 via https://yosemite.epa.gov/oppts/epatscat8.nsf/ReportSearch?OpenForm (date restricted by EPA receipt date), and TSCATS via CDAT (date restricted by ‘Mail Received Date Range’), as well as google for recent TSCA submissions.

The 2017 results were:

- Number of records identified from PubMed, TOXLINE, and TOXCENTER (after duplicate removal): 813
- Number of records identified from other strategies: 35
- Total number of records to undergo literature screening: 848

### B.1.2 Literature Screening

A two-step process was used to screen the literature search to identify relevant studies on 1,2-dibromo-3-chloropropane:

- Title and abstract screen
- Full text screen

Title and Abstract Screen. Within the reference library, titles and abstracts were screened manually for relevance. Studies that were considered relevant (see Table B-1 for inclusion criteria) were moved to the second step of the literature screening process. Studies were excluded when the title and abstract clearly indicated that the study was not relevant to the toxicological profile.

- Number of titles and abstracts screened: 848
- Number of studies considered relevant and moved to the next step: 106

Full Text Screen. The second step in the literature screening process was a full text review of individual studies considered relevant in the title and abstract screen step. Each study was reviewed to determine whether it was relevant for inclusion in the toxicological profile.

- Number of studies undergoing full text review: 106
- Number of studies cited in the health effects sections of the existing toxicological profile (September, 1992): 90
- Total number of studies cited in the health effects sections of the updated profile: 127

A summary of the results of the literature search and screening is presented in Figure B-1.

Figure B-1 March 2017 Literature Search Results and Screen for 1,2-Dibromo-3-chloropropane

Figure showing March 2017 Literature Search Results and Screen for 1,2-Dibromo-3-chloropropane