# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Human Health Sciences, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Division of Toxicology and Human Health Sciences, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-57, Atlanta, Georgia 30329-4027.

## 1,2-Dibromo-3-chloropropane Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2-Dibromo-3-chloropropane
CAS Numbers: | 96-12-8
Date: | September 1992; March 2017—Updated literature search
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL.

Rationale for Not Deriving an MRL: Sufficient information was not available on the health effects of 1,2-dibromo-3-chloropropane to derive an MRL for acute-duration inhalation exposure. In one study, reproductive effects were noted in rats following acute inhalation exposure to 1,2-dibromo-3-chloropropane (Saegusa et al. 1982). The male reproductive system is a particularly sensitive endpoint for 1,2-dibromo-3-chloropropane toxicity. Available human and animal data indicate that humans and rabbits are more sensitive than rats and mice to 1,2-dibromo-3-chloropropane effects on the male reproductive system. Acute-duration inhalation data for rabbits are lacking; therefore, an acute-duration inhalation MRL was not derived for 1,2-dibromo-3-chloropropane.

Agency Contact (Chemical Manager): Rae T. Benedict, Ph.D.

## 1,2-Dibromo-3-chloropropane Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2-Dibromo-3-chloropropane
CAS Numbers: | 96-12-8
Date: | September 1992; March 2017—Updated literature search
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate
MRL | 0.0002 ppm
Critical Effect: | Changes in spermatogenesis and testicular atrophy
Reference: | Rao et al. 1982
Point of Departure: | NOAEL of 0.1 ppm
Uncertainty Factor: | 100
LSE Graph Key: | 9
Species: | Rabbit

MRL Summary: An intermediate-duration inhalation MRL of 0.0002 ppm was derived for 1,2-dibromo-3-chloropropane. The MRL is based on a NOAEL of 0.1 ppm and a LOAEL of 1 ppm for changes in spermatogenesis and testicular atrophy in rabbits exposed to 1,2-dibromo-3-chloropropane for 6 hours/day, 5 days/week for up to 14 weeks (Rao et al. 1982). The NOAEL was adjusted for intermittent exposure, converted to a human equivalent concentration (assuming a value of 1 for ratio of blood/gas partition coefficients), and divided by an uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

Selection of the Critical Effect: No human data are available. Intermediate-duration inhalation data for animals include a series of studies in rats, rabbits, guinea pigs, and monkeys (Torkelson et al. 1961); 13-week studies in rats and mice (NTP 1982); a 14-week study in rats (Rao et al. 1983); and an 8–14-week study in rabbits (Rao et al. 1983). Table A-1 summarizes available NOAEL and LOAEL values for noncancer health effects in animals following intermediate-duration inhalation exposure to 1,2-dibromo-3-chloropropane. The lowest LOAEL value of 1 ppm is associated with testicular effects in rabbits (Rao et al. 1982); respiratory, hepatic, and renal effects in rats (NTP 1982; Reznik et al. 1980a); and endocrine effects in rats (Rao et al. 1983). Among available intermediate-duration inhalation studies, reproductive toxicity was selected as the critical effect because male reproductive effects have been reported in multiple animal species and in humans.

Selection of the Principal Study: Male reproductive effects have been reported in studies of rats and rabbits following intermediate-duration inhalation exposure to 1,2-dibromo-3-chloropropane (NTP 1982; Rao et al. 1982; Torkelson et al. 1961). The study in rabbits (Rao et al. 1982) identified the lowest LOAEL and corresponding NOAEL for reproductive effects, indicating that rabbits may be more sensitive than rats to 1,2-dibromo-3-chloropropane-induced male reproductive effects. Therefore, the rabbit study (Rao et al. 1982) was selected as the principal study for deriving an intermediate-duration inhalation MRL for 1,2-dibromo-3-chloropropane.

Table A-1 Summary of Relevant NOAEL and LOAEL Values from Studies Considered for Derivation of an Intermediate-Duration Inhalation MRL for 1,2-Dibromo-3-Chloropropane

Species | Duration/route | NOAEL (ppm) | LOAEL (ppm) | Effect | Reference
Reproductive effects
Unspecified rat strain | ≤10 weeks; 5 days/week; 7 hours/day | | 5 | Testicular atrophy | Torkelson et al. 1961
New Zealand White rabbit | 14 weeks; 5 days/week; 6 hours/day | 0.1 | 1.0 | Testicular atrophy, sperm abnormalities, decreased serum FSH | Rao et al. 1982
Respiratory effects
F344 rat | 13 weeks; 5 days/week; 6 hours/day | | 1 | Respiratory tract lesions (necrotic and proliferative) | NTP 1982; Reznik et al. 1980a
B6C3F1 mouse | 13 weeks; 5 days/week; 6 hours/day | 1 | 5 | Respiratory tract lesions (necrotic and proliferative) | NTP 1982; Reznik et al. 1980a
Body weight effects
Unspecified rat strain | ≤10 weeks; 5 days/week; 7 hours/day | Not determined | 5 | Depressed body weight gain | Torkelson et al. 1961
Hepatic effects
F344 rat | 13 weeks; 5 days/week; 6 hours/day | Not determined | 1 | Hydropic changes of hepatocytes | NTP 1982; Reznik et al. 1980a
Renal effects
F344 rat | 13 weeks; 5 days/week; 6 hours/day | | 1 | Nephrosis | NTP 1982; Reznik et al. 1980a
Unspecified rat strain | ≤10 weeks; 5 days/week; 7 hours/day | | 5 | Unspecified epithelial changes in renal collecting tubules | Torkelson et al. 1961
Endocrine effects
Sprague-Dawley rat | 4 or 14 weeks; 5 days/week; 6 hours/day | 0.1 | 1 | Hyperplastic nodules in adrenal gland | Rao et al. 1983
Ocular effects
Unspecified rat strain | ≤10 weeks; 5 days/week; 7 hours/day | | 5 | Ocular irritation | Torkelson et al. 1961

FSH = follicle stimulating hormone; LOAEL = lowest observed adverse effect level; NOAEL = no-observed-adverse-effect level; WBCs = white blood cells

Summary of the Principal Study:

Rao KS, Burek JD, Murray FJ, . 1982. Toxicologic and reproductive effects of inhaled 1,2-dibromo-3-chloropropane in male rabbits. Fundam Appl Toxicol 2:241–251.6821042

Groups of male New Zealand White rabbits were exposed by inhalation to 0, 0.1, 1.0, or 10 ppm of 1,2-dibromo-3-chloropropane for 6 hours/day, 5 days/week for up to 14 weeks. Semen was evaluated weekly during the exposure period and periodically during a 32- or 38-week recovery period. Fertility was assessed by mating males with unexposed females at study weeks 14 and 41. At sacrifice, male reproductive organs and tissues were processed for gross and histopathologic evaluations. Exposure at 10 ppm was terminated at week 8 due to two mortalities. Exposure concentration-related increasing severity of gross and histopathologic testicular effects were noted at 1.0 and 10 ppm exposure levels. Surviving 10 ppm rabbits were infertile. Evidence of recovery was noted during the recovery period. An equivocal increase in abnormal sperm was reported among the 0.1 ppm males at week 14, which was not evident at the end of the recovery period; therefore, the 0.1 ppm exposure level was considered a NOAEL for testicular effects.

Selection of the Point of Departure for the MRL: The NOAEL of 0.1 ppm was selected as the basis for the MRL.

Intermittent Exposure: The NOAEL was adjusted from intermittent exposure (6 hours/day, 5 days/week) to account for continuous exposure:

- NOAEL of 0.1 ppm × 6 hours/24 hours × 5 days/7 days = 0.0179 ppm (NOAEL_ADJ_)

Human Equivalent Concentration: The duration-adjusted NOAEL was converted to a human equivalent concentration (assuming a value of 1 for ratio of blood/gas partition coefficients):

- NOAEL_ADJ_ = NOAEL_HEC_ = 0.0179 ppm

Uncertainty Factor: The human equivalent NOAEL was divided by a total uncertainty factor of 100:

- 10 for extrapolation from animals to humans
- 10 for human variability

- MRL = NOAEL_HEC_ ÷ uncertainty factors
  - 0.0179 ppm ÷ (10 × 10) ≈ 0.0002 ppm

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Testicular effects were also observed in rats repeatedly exposed to 1,2-dibromo-3-chloropropane vapor for 2–13 weeks (NTP 1982; Saegusa et al. 1982; Torkelson et al. 1961).

Agency Contact (Chemical Manager): Rae T. Benedict, Ph.D.

## 1,2-Dibromo-3-chloropropane Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2-Dibromo-3-chloropropane
CAS Numbers: | 96-12-8
Date: | September 1992; March 2017—Updated literature search
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL.

Rationale for Not Deriving an MRL: Information regarding effects following chronic-duration inhalation exposure to 1,2-dibromo-3-chloropropane was available for rats and mice (NTP 1982). The lowest LOAEL for nonneoplastic effects was 0.6 ppm (the lowest exposure level tested in rats and mice of NTP 1982); effects included inflammation and hyperplasia in nasal cavity and hyperplasia in lungs; hyperkeratosis and acanthosis in forestomach; and hyperplasia in the urinary bladder and inflammation in the kidney. These nonneoplastic lesions may represent precancerous lesions as a variety of nasal cavity tumors were also observed at this exposure level. In the absence of adequate data regarding nonneoplastic effects in laboratory animals exposed to 1,2-dibromo-3-chloropropane that would not be considered potential precancerous lesions, the database of information is considered inadequate to derive a chronic-duration inhalation MRL for 1,2-dibromo-3-chloropropane.

Agency Contact (Chemical Manager): Rae T. Benedict, Ph.D.

## 1,2-Dibromo-3-chloropropane Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2-Dibromo-3-chloropropane
CAS Numbers: | 96-12-8
Date: | September 1992; March 2017—Updated literature search
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL.

Rationale for Not Deriving an MRL: Several studies provided information on LD_50_ values and selected nonneoplastic effects following acute oral exposure to 1,2-dibromo-3-chloropropane. However, among the available acute-duration oral studies, no acute-duration oral MRL was derived for 1,2-dibromo-3-chloropropane because dominant lethality (which represents a serious LOAEL) was observed at the lowest dose tested (10 mg/kg/day) (Teramoto et al. 1980).

Agency Contact (Chemical Manager): Rae T. Benedict, Ph.D.

## 1,2-Dibromo-3-chloropropane Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2-Dibromo-3-chloropropane
CAS Numbers: | 96-12-8
Date: | September 1992; March 2017—Updated literature search
Profile Status: | Final
Route: | Oral
Duration: | Intermediate
MRL | 0.002 mg/kg/day
Critical Effect: | Decreased spermatogenesis and increased abnormal sperm morphology
Reference: | Foote 1986a, 1986b
Point of Departure: | LOAEL of 1.88 mg/kg/day
Uncertainty Factor: | 1,000
LSE Graph Key: | 22
Species: | Rabbit

MRL Summary: An intermediate-duration oral MRL of 0.002 mg/kg/day was derived for 1,2-dibromo-3-chloropropane. The MRL is based on a LOAEL of 1.88 mg/kg/day for effects on spermatogenesis and sperm morphology in rabbits administered 1,2-dibromo-3-chloropropane in the drinking water for 10 weeks (Foote et al. 1986a, 1986b). The LOAEL was divided by an uncertainty factor of 1,000 (10 for use of a LOAEL, 10 for extrapolation from animals to humans, and 10 for human variability).

Selection of the Critical Effect: No human data are available. Intermediate-duration oral data for animals include a 77-day gavage study in rats (Amann and Berndtson 1986); 60- and 64-day drinking water studies in rats (Heindel et al. 1989; Johnston et al. 1986); a 90-day feeding study in rats (Torkelson et al. 1961); 6-week gavage studies in rats and mice (NCI 1978); 128- and 140-day gavage studies in mice (Reel et al. 1984); and a 10-week drinking water study in rabbits (Foote et al. 1986b). Table A-2 summarizes relevant NOAEL and LOAEL values for noncancer health effects in animals following intermediate-duration oral exposure to 1,2-dibromo-3-chloropropane from studies that serve as candidate principal studies for deriving an intermediate-duration oral MRL. Among available intermediate-duration oral studies, male reproductive toxicity was selected as the critical effect because it represents the lowest LOAEL, which is lower than the lowest NOAEL for other effects.

Selection of the Principal Study: Male reproductive effects have been reported in studies of rats and rabbits following intermediate-duration oral exposure to 1,2-dibromo-3-chloropropane (Amann and Berndtson 1986; Foote et al. 1986a, 1986b; Heindel et al. 1989; Johnston et al. 1986). The study in rabbits (Foote et al. 1986a, 1986b) identified the lowest LOAEL for male reproductive effects, indicating that rabbits may be more sensitive than rats to 1,2-dibromo-3-chloropropane-induced male reproductive effects. Therefore, the rabbit study (Foote et al. 1986a, 1986b) was selected as the principal study for deriving an intermediate-duration oral MRL for 1,2-dibromo-3-chloropropane.

Table A-2 Summary of Relevant NOAEL and LOAEL Values from Studies Considered for Derivation of an Intermediate-Duration Oral MRL for 1,2-Dibromo-3-Chloropropane

Species | Duration/route | NOAEL (ppm) | LOAEL (ppm) | Effect | Reference
Reproductive effects
Dutch rabbit | 10 weeks; 5 days/week in drinking water | 0.94^a^ | 1.88 | Abnormal sperm morphology, decreased spermatogenesis | Foote et al. 1986b
Body weight effects
Sprague-Dawley rat | 64 days in drinking water | 5.4 | 9.7 | Depressed body weight gain | Heindel et al. 1989
Unspecified rat strain | 90 days in food | 2.5 | 7.5 | Depressed body weight gain | Torkelson et al. 1961
Renal effects
Sprague-Dawley rat | 64 days in drinking water | 3.3 | 5.4 | Increased turnover of proximal tubular cells | Heindel et al. 1989

a The study authors stated the following: “The no effect level for DBCP administered to male rabbits in drinking water appears to be about 0.94 mg/kg for the most sensitive indicators of testicular function measured, if one accepts the null hypothesis at p=0.05. Because means were slightly higher for controls, on this basis the no effect level is <0.94 mg/kg of body weight.” For this reason, the 0.94 mg/kg/day dose level is not used as basis for deriving an intermediate-duration oral MRL for 1,2-dibromo-3-chloropropane.

DBCP = 1,2-dibromo-3-chloropropane; GD = gestation day; LOAEL = lowest observed adverse effect level; NOAEL = no-observed-adverse-effect level; PPD = postpartum day

Summary of the Principal Study:

Foote RH, Berndtson WE, Rounsaville TR. 1986a. Use of quantitative testicular histology to assess the effect of dibromochloropropane (DBCP) on reproduction in rabbits. Fundam Appl Toxicol 6:638–647.3710034

Foote RH, Schermerhorn EC, Simkin ME. 1986b. Measurement of semen quality, fertility, and reproductive hormones to assess dibromochloropropane (DBCP) effects in live rabbits. Fundam Appl Toxicol 6:628–637.3086172

Groups of male Dutch belted rabbits (6/group) were administered 1,2-dibromo-3-chloropropane in the drinking water 5 days/week for 10 weeks at concentrations resulting in 1,2-dibromo-3-chloropropane intakes of 0, 0.94, 1.88, 3.75, 7.5, or 15 mg/kg/day during each 5-day period. Ejaculate was evaluated periodically during the exposure period for volume, percent motile sperm, and sperm concentration. Fertility was assessed by mating males with unexposed females during the last week of the study or collecting ejaculate and artificially inseminating unexposed females. Blood levels of FSH, LH, and testosterone were determined during the last week of the study as well. At sacrifice, epididymal sperm was collected for analysis and reproductive organs and tissues were processed for gross and histopathologic evaluations. There were no treatment-related effects on blood LH or testosterone levels. High-dose rabbits exhibited significantly elevated blood FSH (consistent with impaired spermatogenesis). Percent normal sperm was significantly decreased at the two highest dose levels; mean seminiferous tubule diameter was significantly reduced at these dose levels as well. Testicular weight was significantly decreased in high-dose rabbits (55% less than controls). Mean numbers of spermatogonia per stage I seminiferous tubular cross section were significantly decreased at doses ≥1.88 mg/kg/day (mean numbers for controls, 0.94, 1.88, 3.75, 7.5, and 15 mg/kg/day dose groups were 2.3±0.13 [SE], 2.0±0.13, 1.8±0.12, 1.6±0.12, 1.5±0.12, and 1.0±0.15, respectively). Mean numbers of preleptotene primary spermatocytes per stage I seminiferous tubular cross-section were significantly decreased at doses ≥1.88 mg/kg/day as well (mean numbers for controls, 0.94, 1.88, 3.75, 7.5, and 15 mg/kg/day dose groups were 42.5±0.2.4, 41.9±2.4, 35.0±2.2, 29.3±2.2, 26.0±2.2, and 13.6±2.6, respectively). Dose-related increases in percent abnormal sperm were noted starting with the 1.88 mg/kg/day dose level. At the highest dose, mean testes weight was 55% less than that of controls. Dose-related decreased mean seminiferous tubular diameter was noted at the two highest dose levels. There was no apparent treatment-related effect on fertility. The 1.88 mg/kg/day dose level is considered a LOAEL for effects on sperm morphology.

Selection of the Point of Departure for the MRL: The LOAEL of 1.88 mg/kg/day was selected as the basis for the MRL.

Intermittent Exposure: No adjustment was made for treatment in the drinking water for only 5 days/week.

Uncertainty Factor: The LOAEL was divided by a total uncertainty factor of 1,000:

- 10 for use of a LOAEL
- 10 for extrapolation from animals to humans
- 10 for human variability

- MRL = LOAEL ÷ uncertainty factors
  - 1.88 mg/kg/day ÷ (10 × 10 × 10) ≈ 0.002 mg/kg/day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Testicular effects were also observed in rats orally exposed to 1,2-dibromo-3-chloropropane for 60–77 days (Amann and Berndtson 1986; Heindel et al. 1989; Johnston et al. 1986).

Agency Contact (Chemical Manager): Rae T. Benedict, Ph.D.

## 1,2-Dibromo-3-chloropropane Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,2-Dibromo-3-chloropropane
CAS Numbers: | 96-12-8
Date: | September 1992; March 2017—Updated literature search
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL.

Rationale for Not Deriving an MRL: Available chronic-duration oral data are not suitable for MRL development. The lowest LOAEL is 1 mg/kg/day for hyperkeratosis and acanthosis in the gastrointestinal tract of rats (Hazleton 1977, 1978a, 1978b). The same study reported liver, kidney, and stomach tumors at the next higher dose level (3 mg/kg/day). The nonneoplastic stomach lesions may be representative of precancerous lesions. NOAELs and LOAELs for other endpoints are higher than the lowest LOAEL and corresponding NOAEL for intermediate-duration oral exposure. Therefore, a chronic-duration oral MRL was not derived for 1,2-dibromo-3-chloropropane.

Agency Contact (Chemical Manager): Rae T. Benedict, Ph.D.