# 9 REFERENCES

ACGIH. 2014. 1,1-Dichloroethane. In: TLVs and BEIs based on the documentation of the threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists, 24.
Adlercreutz H. 1995. Phytoestrogens: Epidemiology a nd a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
Agency for Toxic Substances and Disease Registry. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry, Division of Toxicology. Fed Regist 54(174):37618–37634.
AIHA. 2014. Current ERPG Values (2014). Fairfax, VA: American Industrial Hygiene Association. https://www.aiha.org/get-involved/AIHAGuidelineFoundation/EmergencyResponsePlanningGuidelines/Documents/2014%20ERPG%20Values.pdf. March 4, 2015.
Altman PL, Dittmer DS. 1974. Biological handbooks: Biology data book. Vol. III. 2nd ed. Bethesda, MD: Federation of American Societies for Experimental Biology, 1987–2008, 2041.
Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York, NY: Marcel Dekker, Inc., 9–25.
Andersen ME, Clewell HJ, Gargas ML, 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87(2):185–205.3824380
Andrews JE, Nichols H, Hunter ES. 2002. Developmental toxicity of di- and tetrachloroethane and dichloropropane in the rat whole embryo culture system [Abstract]. Toxicologist 66(1-S):23.
Archer WL. 1978. Other chloroethanes. In: Kirk-Othmer encyclopedia of chemistry and technology. Vol. 5, 3rd ed. New York, NY: John Wiley and Sons, Inc., 722–742.
Ashley DL, Bonin MA, Cardinali FL, 1992. Determining volatile organic compounds in human blood from a large sample population by using purge and trap gas chromatography/mass spectrometry. Anal Chem 64:1021–1029.1590585
Baker RJ, Andraski BJ, Stonestrom DA, 2012. Volatile organic compounds in the unsaturated zone from radioactive wastes. J Environ Qual 41(4):1324–1336. I 10.2134/jeq2011.0480. 22751077
Barkley J, Bunch J, Bursey JT, 1980. Gas chromatography mass spectrometry computer analysis of volatile halogenated hydrocarbons in man and his environment - a multimedia environmental study. Biomed Mass Spectrom 7:139–147.7448328
Barsky JB, Hee SSQ, Clark CS. 1985. An evaluation of the response of some portable, direct-reading 10.2 electron volt and 11.8 electron volt photoionization detectors and a flame ionization gas chromatograph for organic vapors in high humidity atmospheres. Am Ind Hyg Assoc J 46:9–14.4025151
Bauer S, Solyom D. 1994. Determination of volatile organic compounds at the parts per trillion level in complex aqueous matrices using membrane introduction mass spectrometry. Anal Chem 66(24):4422–4431.
Bellar TA, Budde WL, Eichelberger JW. 1979. The identification and measurement of volatile organic compounds in aqueous environmental samples. In: Schuetzle D, ed. Monitoring toxic substances. American Chemical Society Symposium Series No. 94. Washington, DC: American Chemical Society, 49–62.
Berger GS, ed. 1994. Epidemiology of endometriosis. In: Endometriosis: Advanced management and surgical techniques. New York, NY: Springer-Verlag, 3–7.
Bi E, Liu Y, He J, 2012. Screening of emerging volatile organic contaminants in shallow groundwater in east China. Ground Water Monit Remed 32(1):53–58. I 10.1111/j.1745–6592.2011.01362.x.
Blanchard RD, Hardy JK. 1985. Use of a permeation sampler in the collection of 23 volatile organic priority pollutants. Anal Chem 57:2349–2351.
Blanchard RD, Hardy JK. 1986. Continuous monitoring device for the collection of 23 volatile organic priority pollutants. Anal Chem 58:1529–1532.
Boman A, Maibach H. 1996. Influence of evaporation and repeated exposure on the percutaneous absorption of organic solvents. In: Elsner P, Lachapelle JM, Wahlberg JE, , eds. Current problems in dermatology (Basel), Vol. 25. Prevention of Contact Dermatitis; International Conference on the Prevention of Contact Dermatitis, Zurich, Switzerland, October 4–7, 1995, 47–56.
Bronzetti G, Galli A, Vellosi R, 1987. Genetic activity of chlorinated ethanes [Abstract]. Eur J Cancer Clin Oncol 23:1737–1738.
Bruner F, Bertoni G, Crescentini G. 1978. Critical evaluation of sampling and gas chromatographic analysis of halocarbons and other organic air pollutants. J Chromatogr 167:399–407.757592
Buckley TJ, Liddie J, Ashley DL, 1997. Environmental and biomarker measurements in nine homes in the lower Rio Grande Valley: Multimedia results for pesticides, metals, PAHs, and VOCs. Environ Int 23(5):705–732.
Cadena F, Eiceman GA, Vandiver VJ. 1984. Removal of volatile organic pollutants from rapid streams. J Water Pollut Control Fed 56:391–490.
Cal EPA. 2003. Public health goal for 1,1-dichloroethane in drinking water. California Environmental Protection Agency, Office of Environmental Health Hazard Assessment.
CDC. 2015. Fourth national report on human exposure to environmental chemicals. Centers for Disease Control and Prevention. http://www.cdc.gov/biomonitoring/pdf/FourthReport_UpdatedTables_Feb2015.pdf. March 10, 2015.
ChemIDplus Lite. 2012. 1,1-Dichloroethane. http://chem.sis.nlm.nih.gov/chemidplus/ProxyServlet?objectHandle=Search&actionHandle. February 13, 2012.
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Cline PV, Viste DR. 1985. Migration and degradation patterns of volatile organic compounds. Waste Manag Res 3:351–360.
Colacci A, Arfellini G, Mazzullo M, 1985. Genotoxicity of 1,1-dichloroethane. Res Commun Chem Pathol Pharmacol 49:243–254.2414829
Cole RH, Frederick RE, Healy RP, 1984. Preliminary findings of the priority pollutant monitoring project of the Nationwide Urban Runoff Program. J Water Pollut Control Fed 56:898–908.
Comba ME, Kaiser KLE. 1983. Determination of volatile contaminants at the ng/l level in water by capillary gas chromatography with electron capture detection. Int J Environ Anal Chem 16:17–31.
Coniglio WA, Miller K, MacKeever D. 1980. The occurrence of volatile organics in drinking water. Briefing for the Deputy Assistant Administrator for Drinking Water, March 1980.
Costa LG, Aschner M, Vitalone A, 2004. Developmental neuropathology of environmental agents. Annu Rev Pharmacol Toxicol 44:87–110. 10.1146/annurev.pharmtox.44.101802.121424. 14744240
Cowfer JA, Gorenser MB, Company TG. 2006. Vinyl chloride. In: Kirk-Othmer encyclopedia of chemical technology. New York, NY: John Wiley & Sons, Inc., 1–31.
Cramer PH, Boggess K, Hosenfeld JM, 1988. Determination of organic chemicals in human whole blood: Preliminary method development for volatile organics. Bull Environ Contam Toxicol 40:612–618.3370355
Cupitt LT. 1980. Fate of toxic and hazardous materials in the air environment. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA600S380084.
Daft JL. 1988. Rapid determination of fumigant and industrial chemical residues in food. J Assoc Off Anal Chem 71:748–760.3417594
de Best JH, Jongema H, Weijling A, 1997. Transformation of 1,1,1-trichloroethane in an anaerobic packed-bed reactor at various concentrations of 1,1,1-trichloroethane, acetate and sulfate. Appl Microbiol Biotechnol 48(3):417–423.
Dewulf J, Dewettinck T, De Visscher A, 1996. Sorption of chlorinated C_1_- and C_2_-hydrocarbons and monocyclic aromatic hydrocarbons on sea sediment. Water Res 30(12):3130–3138.
Dilling WL. 1977. Interphase transfer processes. II. Evaporation rates of chloromethanes, ethanes, ethylenes, propanes, and propylenes from dilute aqueous solutions. Comparisons with theoretical predictions. Environ Sci Technol 11:405–409.
Dilling WL, Tefertiller NB, Kallos GJ. 1975. Evaporation rates and reactivities of methylene chloride, chloroform, 1,1,1-trichloroethane, trichloroethylene, tetrachloroethylene, and other chlorinated compounds in dilute aqueous solutions. Environ Sci Technol 9:833–837.
DOE. 2005. Interim sanitary landfill 2005 annual groundwater report. U.S. Department of Energy. WSRC-TR-2005–00548.
DOE. 2012a. Table 3: PACs by CASRN (pdf). PAC Rev 27 Tables - PAC data and chemical properties presented in pdf and excel tables. Protective Action Criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 27 for Chemicals of Concern - March 2012. Oak Ridge, TN: U.S. Department of Energy. http://energy.gov/ehss/protective-action-criteria-pac-aegls-erpgs-teels-rev-27-chemicals-concern-march-2012. March 4, 2015.
DOE. 2012b. Protective action criteria (PAC): Chemicals with AEGLs, ERPGs, & TEELs. Definition of PACs (AEGLs, ERPGs or TEELs). Protective Action Criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 27 for Chemicals of Concern - March 2012. Oak Ridge, TN: U.S. Department of Energy. http://energy.gov/ehss/protective-action-criteria-pac-aegls-erpgs-teels-rev-27-chemicals-concern-march-2012. March 24, 2015.
Dreher EL, Beutel KK, Myers JD, 2014. Chloroethanes and chloroethylenes. In: Ullmann's encyclopedia of industrial chemistry. Vol. 10.1002/14356007.o06_o01.pub2.
Dreisch FA, Munson TO. 1983. Purge-and-trap analysis using fused silica capillary column gas chromatography-mass spectrometry. J Chromatogr Sci 21:111–118.
Driscoll JN, Duffy M, Pappas S, 1987. Analysis for purgeable organics in water by capillary GC/PID-EICD. J Chromatogr Sci 25:369–375.
Easley DM, Kleopfer RD, Carasea AM. 1981. Gas chromatographic-mass spectrometric determination of volatile organic compounds in fish. J Assoc Off Anal Chem 64:653–656.7240070
Eitzer BD. 1995. Emissions of volatile organic chemicals from municipal solid waste composting facilities. Environ Sci Technol 29:896–902.22176396
Ek CJ, Dziegielewska KM, Habgood MD, 2012. Barriers in the developing brain and neurotoxicology. Neurotoxicology 33(3):586–604. 10.1016/j.neuro.2011.12.009. 22198708
EPA. 1978. Quantification of chlorinated hydrocarbons in previously collected air samples. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA450378112.
EPA. 1980. Ambient water quality criteria for chlorinated ethanes. Washington, DC: U.S. Environmental Protection Agency, Office of Water Regulations and Standards, Criteria and Standards Division. EPA440580029.
EPA. 1982a. An exposure and risk assessment for dichloroethanes. U.S. Environmental Protection Agency. EPA440485009. http://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=40001LDV.txt. June 4, 2015.
EPA. 1982b. Direct measurement of volatile organic compounds in breathing-zone air, drinking water, breath, blood and urine. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA600482015. PB82186545.
EPA. 1983a. Measurements of hazardous organic chemicals in the ambient atmosphere. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Research and Development. EPA600383002. PB83156935.
EPA. 1983b. Volatile organic chemicals in the atmosphere: An assessment of available data. Menlo Park, CA: U.S. Environmental Protection Agency. EPA600S83027.
EPA. 1985. Synthetic organic compound sampling survey of public water supplies. Washington, DC: U.S. Environmental Protection Agency. PB85214427.
EPA. 1993. Analyis of ambient monitoring data in the vicinity of open tire fires. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Air Quality.
EPA. 1994b. Method 8010B. Halogenated volatile organics by gas chromatography. Test methods for evaluating solid waste. U.S. Environmental Protection Agency.
EPA. 1994a. Method 8240B. Volatile organic compounds by gas chromatography/mass spectrometry (GC/MS). Test methods for evaluating solid wastes physical/chemical methods. Washington, DC: U.S. Environmental Protection Agency.
EPA. 1996a. Determination of landfill gas composition and pollutant emission rates at fresh kills landfill. Volume 1. New York, NY: U.S. Environmental Protection Agency.
EPA. 1996b. Method 5030B. Purge-and-trap for aqueous samples. Test methods for evaluating solid wastes physical/chemical methods. U.S. Environmental Protection Agency. http://www.epa.gov/epawaste/hazard/testmethods/sw846/pdfs/5030b.pdf. June 28, 2012.
EPA. 1997. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. EPA630R96012.
EPA. 1999. Appendix A to part 136-methods for organic chemical analysis of municipal and industrial waste-water. Method 624-purgeables. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 136 Appendix A, Method 624. https://www.nemi.gov/apex/f?p=237:38:2361622513108808::::P38_METHOD_ID:5249. June 28, 2012.
EPA. 2000. National air pollutant emission trends, 1900–1998. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards. EPA450R00002.
EPA. 2001a. Appendix A to part 136-methods for organic chemical analysis of municipal and industrial waste-water. Method 601-purgeable halocarbons. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 136 Appendix A, Method 601. https://www.nemi.gov/pls/nemi_pdf/nemi_data.download_pdf?p_file=3091. June 28, 2012.
EPA. 2001b. Appendix A to part 136-method 1624 revision B-volatile organic compounds by isotope dilution GC/MS. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 136 Appendix A, Method 1624. https://www.nemi.gov/pls/nemi_pdf/nemi_data.download_pdf?p_file=3051. June 28, 2012.
EPA. 2001c. Sources, emission and exposure for trichloroethylene(TCE) and related chemicals. Washington, DC: U.S. Environmental Protection Agency, National Center for Environmental Assessment, Office of Research and Development.
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. Office of Environmental Information. EPA260B05001.
EPA. 2009. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency, Office of Ground Water and Drinking Water. EPA816F090004. http://water.epa.gov/drink/contaminants/upload/mcl-2.pdf. March 4, 2015.
EPA. 2010. CAS 75–34-3. Non-confidential 2006 IUR records by chemical, including manufacturing, processing and use information. U.S. Environmental Protection Agency. http://cfpub.epa.gov/iursearch/index.cfm?err=t#chemical. May 16, 2012.
EPA. 2012a. 2012 Edition of the drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency, Office of Water. EPA822S12001. http://water.epa.gov/action/advisories/drinking/upload/dwstandards2012.pdf. March 4, 2015.
EPA. 2012b. National ambient air quality standards (NAAQS). Washington, DC: U.S. Environmental Protection Agency, Office of Air and Radiation. http://www.epa.gov/air/criteria.html. January 08, 2014.
EPA. 2012c. 2005 National emissions inventory data and documentation. U.S. Environmental Protection Agency. http://www.epa.gov/ttn/chief/net/2005inventory.html#inventorydata. May 18, 2012.
EPA. 2013a. Designation of hazardous substances. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 116.4. http://www.gpo.gov/fdsys/pkg/CFR-2014-title40-vol22/pdf/CFR-2014-title40-vol22-sec116–4.pdf. March 4, 2015.
EPA. 2013b. National recommended water quality criteria. Washington, DC: U.S. Environmental Protection Agency, Office of Water, Office of Science and Technology. http://water.epa.gov/scitech/swguidance/standards/criteria/current/index.cfm. March 4, 2015.
EPA. 2013c. Determination of reportable quantities for hazardous substances. Subpart A - General provisions. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 117.3. http://www.gpo.gov/fdsys/pkg/CFR-2014-title40-vol22/pdf/CFR-2014-title40-vol22-sec117-3.pdf. March 4, 2015.
EPA. 2013d. Appendix A to Part 355—The list of extremely hazardous substances and their threshold planning quantities. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 355. http://www.gpo.gov/fdsys/pkg/CFR-2013-title40-vol29/pdf/CFR-2013-title40-vol29-part355-appA.pdf. September 10, 2014.
EPA. 2013e. Appendix VIII to Part 261-Hazardous constituents. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 261, Appendix VIII. http://www.gpo.gov/fdsys/pkg/CFR-2013-title40-vol27/pdf/CFR-2013-title40-vol27-part261-appVIII.pdf. September 10, 2014.
EPA. 2014a. CAS 75–34-3. Pollution prevention and toxics. Chemical Data Access Tool (CDAT). U.S. Environmental Protection Agency. http://java.epa.gov/oppt_chemical_search/. February 26, 2015.
EPA. 2014b. Final AEGLs (162). Washington, DC: U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics. http://www.epa.gov/oppt/aegl/pubs/compiled_aegls_update_03oct2014.pdf. March 4, 2015.
EPA. 2014c. Master testing list. Washington, DC: U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics. http://www.epa.gov/opptintr/chemtest/pubs/index1.pdf. September 10, 2014.
EPA. 2014d. InertFinder. U.S. Environmental Protection Agency. http://iaspub.epa.gov/apex/pesticides/f?p=101:1:. March 31, 2015.
EPA. 2014e. Designation of hazardous substances. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 302.4. http://www.gpo.gov/fdsys/pkg/CFR-2014-title40-vol28/pdf/CFR-2014-title40-vol28-sec302–4.pdf. March 4, 2015.
EPA. 2014f. Chemicals and chemical categories to which this part applies. Subpart D - Specific toxic chemical listings. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 372.65. http://www.gpo.gov/fdsys/pkg/CFR-2014-title40-vol28/pdf/CFR-2014-title40-vol28-sec372-65.pdf. March 4, 2015.
EPA. 2014g. Chemical lists and reporting periods. Subpart B - Manufacturers reporting - Preliminary assessment information. Code of Federal Regulations 40 CFR 712.30. http://www.gpo.gov/fdsys/pkg/CFR-2014-title40-vol31/pdf/CFR-2014-title40-vol31-sec712-30.pdf. April 6, 2015.
EPA. 2014h. Substances and listed mixtures to which this subpart applies. Subpart B - Specific chemical listings. Code of Federal Regulations 40 CFR 716.120. http://www.gpo.gov/fdsys/pkg/CFR-2014-title40-vol31/pdf/CFR-2014-title40-vol31-sec716–120.pdf. April 6, 2015.
EPA. 2015a. Clean water act methods update rule For the analysis of effluent. U.S. Environmental Protection Agency. Fed Regist 80(33):8956–9075.
EPA. 2015b. 1,1-Dichloroethane. Ambient monitoring technology information center. Air toxics data. Air toxics-data analysis. U.S. Environmental Protection Agency. http://www.epa.gov/ttnamti1/toxdat.html#data. April 2, 2015.
EPA. 2015c. National Priorities List (NPL). U.S. Environmental Protection Agency. http://www.epa.gov/superfund/sites/npl/. April 2, 2015.
FDA. 2013. Everything added to food in the United States (EAFUS). Washington, DC: U.S. Food and Drug Administration. http://www.accessdata.fda.gov/scripts/fcn/fcnnavigation.cfm?rpt=eafuslisting. January 08, 2014.
Ferrario JB, Lawler GC, DeLeon IR, 1985. Volatile organic pollutants in biota and sediments of Lake Pontchatrain. Bull Environ Contam Toxicol 34:246–255.3978262
Fomon SJ. 1966. Body composition of the infant: Part I: The male reference infant. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
Fomon SJ, Haschke F, Ziegler EE, 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35(Suppl 5):1169–1175.7081099
Giabbai M, Roland L, Chian ESK. 1983. Trace analysis of organic priority pollutants by high-resolution gas chromatography and selective detectors (FID, ECD, NPD, and MS-DS): Application to municipal wastewater and sludge samples. Chromatogr Biochem Med Environ Res 13:41–52.
Giwercman A, Carlsen E, Keiding N, 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect Suppl 101(2):65–71.
Goodin JD, Webber MD. 1992. The persistence and fate of industrial organics in sludge-treated soil. Can J Soil Sci 72:310–311.
Gossett RW, Brown DA, Young DR. 1983. Predicting the bioaccumulation of organic compounds in marine organisms using octanol/water partition coefficients. Mar Pollut Bull 14:387–392.
Great Lakes Commission. 2006. 2002 Inventory of toxic air emissions for the Great Lakes Region. Ann Arbor, MI: Great Lakes Commission.
Grimsrud EP, Rasmussen RA. 1975. Survey and analysis of halocarbons in the atmosphere by gas chromatography- mass spectrometry. Atmos Environ 9:1014–1017.
Gupta KC, Ulsamer AG, Gammage R. 1984. Volatile organic compounds in residential air: Levels, sources and toxicity. Proceedings of the 77th Air Pollution Control Association Annual Meeting 1:9.
Guzelian PS, Henry CJ, Olin SS, eds. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences Institute Press.
Hallen RT, Pyne JR Jr., Molton PM. 1986. Transformation of chlorinated ethenes and ethanes by anaerobic microorganisms. In: Proceedings of 192nd national meeting: ACS Division of Environmental Chemistry, Vol. 26, 344–346.
Hamonts K, Kuhn T, Vos J, 2012. Temporal variations in natural attenuation of chlorinated aliphatic hydrocarbons in eutrophic river sediments impacted by a contaminated groundwater plume. Water Res 46(6):1873–1888. I 10.1016/j.watres.2012.01.001. 22280951
Hatch GG, Mamay PD, Ayer ML, 1983. Chemical enhancement of viral transformation in Syrian hamster embryo cells. Cancer Res 43:1945–1950.6299533
HazDat. 2007. 1,1-Dichloroethane. HazDat Database: ATSDR’s Hazardous Substance Release and Health Effects Database. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
Heikes DL, Jensen SR, Fleming-Jones ME. 1995. Purge and trap extraction and GC-MS determination of volatile organic compounds in table-ready food. J Agric Food Chem 43:2869–2875.
Herren-Freund SL, Pereira MA. 1986. Carcinogenicity of by-products of disinfection in mouse and rat liver. Environ Health Perspect 69:59–65.2880712
Hiatt MH. 1981. Analysis of fish and sediment for volatile priority pollutants. Anal Chem 53:1541–1543.7270902
Hiatt MH. 1983. Determination of volatile organic compounds in fish samples by vacuum distillation and fused silica capillary gas chromatography/mass spectrometry. Anal Chem 55:506–516.6846846
Hoel DG, Davis DL, Miller AB, 1992. Trends in cancer mortality in 15 industrialized countries, 1969–1986. J Natl Cancer Inst 84(5):313–320.1738181
Hofmann HT, Birnstiel H, Jobst P. 1971. [Inhalation toxicity of 1,1- and 1,2-dichloroethane]. Arch Toxikol 27:248–265. (German).5579438
Howard CJ, Evenson KM. 1976. Rate constants for the reactions of OH with ethane and some halogen substituted ethanes at 296 K. J Chem Phys 64:4303–4306.
HSDB. 2012. 1.1-Dichloroethane. Hazardous Substances Data Bank. National Library of Medicine. http://toxnet.nlm.nih.gov. May 14, 2012.
Huybrechts T, Dewulf J, Van Craeynest K, 2001. Evaluation of tetraglyme for the enrichment and analysis of volatile organic compounds in air. J Chromatogr A 922(1–2):207–218.11486865
IARC. 2012. Agents classified by the IARC Monographs. Volumes 1–104. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Classification/ClassificationsCASOrder.pdf. April 25, 2012.
IARC. 2015. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Classification/ClassificationsCASOrder.pdf. March 31, 2015.
Infante PF, Tsongas TA. 1982. Mutagenic and oncogenic effects of chloromethanes. Chloromethanes and halogenated analogues of vinyl chloride. Environ Sci Res 25:301–327.
IRIS. 2002. 1,1-Dichloroethane (CASRN 75–34-3). Integrated Risk I nformation System. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/iris/subst/0409.htm. April 6, 2015.
Jeffers PM, Ward LM, Woytowitch LM, Wolfe NL. 1989. Homogeneous hydrolysis rate constants for selected chlorinated methanes, ethanes, ethenes, and propanes. Environ Sci Technol 23:965–969.
Jerpe J, Davis A. 1987. Ambient capillary chromatography of volatile organics with a portable gas chromatograph. J Chromatogr Sci 25:154–157.
Kallonen R, von Wright A, Tikkanen L, 1985. The toxicity of fire effluents from textiles and upholstery materials. J Fire Sci 3:145–160.
Kearns GL, Abdel-Rahman SM, Alander SW, 2003. Developmental pharmacology-drug disposition, action, and therapy in infants and children. N Engl J Med 349(12):1157–1167. 10.1056/NEJMra035092. 13679531
Kim HF, Bruckner JV, Dallas CE, 1990b. Effect of dosing vehicles on the pharmacokinetics of orally administered carbon tetrachloride in rats. Toxicol Appl Pharmacol 102:5060.
Kim HJ, Odend'hal S, Bruckner JV. 1990a. Effect of oral dosing vehicles on the acute hepatotoxicity of carbon tetrachloride in rats. Toxicol Appl Pharmacol 102:34–49.2296770
Kim KH, Ho DX, Park CG, 2012. Volatile organic compounds in ambient air at four residential locations in Seoul, Korea. Environ Eng Sci 29(9):875–889. I 10.1089/ees.2011.0280. 22969269
Kingsley BA, Gin C, Coulson DM, 1983. Gas chromatographic analysis of purgeable halocarbon and aromatic compounds. Water Chlorination: Environmental Impact and Health Effects 4:593–608.
Klaunig JE, Ruch RJ, Pereira MA. 1986. Carcinogenicity of chlorinated methane and ethane compounds administered in drinking water to mice. Environ Health Perspect 69:89–95.3816740
Klecka GM, Gonsior SJ, Markham DA. 1990. Biological transformations of 1,1,1-trichloroethane in subsurface soils and ground water. Environ Toxicol Chem 9(12):1437–1452.
Kolpin DW, Squillace PJ, Zogorski JS. 1997. Pesticides and volatile organic compounds in shallow urban groundwater of the United States. In: Groundwater in the urban environment: Problems, processes and management. Rotterdam: Balkema, 469–474.
Komori M, Nishio K, Kitada M, 1990. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry 29(18):4430–4433.2350547
Konietzko H. 1984. Chlorinated ethanes: Sources, distribution, environmental impact, and health effects. In: Saxena J, ed. Hazard assessment of chemicals: Current developments. Orlando, FL: Academic Press, 3:401–448.
Krill RM, Sonzogni WC. 1986. Chemical monitoring of Wisconsin's groundwater. J Am Water Works Assoc 78:70–75.
Krishnan K, Andersen ME. 1994. Physiologically based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. 3rd ed. New York, NY: Raven Press, Ltd., 149–188.
Krishnan K, Andersen ME, Clewell HJ, 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures: Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Leeder JS, Kearns GL. 1997. Pharmacogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44(1):55–77.9057784
Leung HW. 1993. Physiologically-based pharmacokinetic modelling. In: Ballentyne B, Marrs T, Turner P, eds. General and applied toxicology. Vol. 1. New York, NY: Stockton Press, 153–164.
Lewis RJ. 2004. 1,1-Dichloroethane. In: Sax's dangerous properties of industrial materials. 11th ed. Hoboken, NJ: John Wiley & Sons, 1189.
Livingston AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4(2–3):301–324.351201
Lopez-Avila V, Heath N, Hu A. 1987b. Determination of purgeable halocarbons and aromatics by photoionization and hall electrolytic conductivity detectors connected in series. J Chromatogr Sci 25:356–363.
Lopez-Avila V, Wood R, Flanagan M, 1987a. Determination of volatile priority pollutants in water by purge and trap and capillary column gas chromatography/mass spectrometry. J Chromatogr Sci 25:286–291.3611283
Mabey WR, Smith JH, Podoll TT, 1982. Aquatic fate process data for organic priority pollutants. Washington, DC: U.S. Environmental Protection Agency, Office of Water Regulations and Standards. EPA440481014.
Maeda T, Funaki K, Yanaguchi Y, 1998. On-site monitoring system for hazardous air pollutants using an adsorption-thermal desorption-capillary GC system equipped with a photoionization detector and an electrolytic conductivity detector. J High Resolut Chromatogr 21(8):471–474.
Marshall KA. 2003. Chlorocarbons and chlorohydrocarbons, survey. In: Kirk-Othmer encyclopedia of chemical technology. New York, NY: John Wiley & Sons, Inc., 226–253.
Matsuoka A, Hayashi M, Sofuni T. 1998. In vitro clastogenicity of 19 organic chemicals found in contaminated water and 7 structurally related chemicals. Kenkyo Hen'igen Kenkyu 20(3):159–165.
Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74(2–3):135–149.1387742
McCall SN, Jurgens P, Ivanetich KM. 1983. Hepatic microsomal metabolism of the dichloroethanes. Biochem Pharmacol 32:207–213.6870950
Mehran M, Cooper WJ, Mehran M, e t al. 1986. Comparison of direct headspace and aqueous injection techniques for halogenated hydrocarbons in water. J Chromatogr Sci 24:142–146.
Miller KW, Paton WDM, Smith EB. 1965. Site of action of general anaesthetics GA. Nature 206:574–577.5890773
Milman HA, Story DL, Riccio ES, 1988. Rat liver foci and in vitro assays to detect initiating and promoting effects of chlorinated ethanes and ethylenes. Ann N Y Acad Sci 534:521–530.3389679
Mitoma C, Steeger T, Jackson SE, 1985. Metabolic disposition study of chlorinated hydrocarbons in rats and mice. Drug Chem Toxicol 8:183–194.4054011
Mohamed MF, Kang D, Aneja VP. 2002. Volatile organic compounds in some urban locations in United States. Chemosphere 47:863–882.12079081
Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokin 5(6):485–527.
NAS/NRC. 1989. Report of the oversight committee. In: Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press, 15–35.
NCI. 1977. Bioassay of 1,1-dichloroethane for possible carcinogenicity. Bethesda, MD: National Cancer Institute. NIH publication No. 78–1316.
Needham LL, Ashley DL, Hill RH, 1995. Human levels of selected non-persistent chlorinated compounds. Organohalogen Comp 26:35–38.
NIOSH. 1978. Occupational health guidelines for 1,1-dichloroethane. Occupational health guidelines for chemical hazards. Washington, DC: US Department of Labor, National Institute for Occupational Safety and Health, 1–4.
NIOSH. 2003. Method 1003. Hydrocarbons, halogenated. NIOSH manual of analytical methods. National Institute for Occupational Safety and Health http://www.cdc.gov/niosh/docs/2003-154/pdfs/1003.pdf. June 28, 2012.
NIOSH. 2011. 1,1-Dichloroethane. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. http://www.cdc.gov/niosh/npg/. April 25, 2012.
NIOSH. 2015. 1,1-Dichloroethane. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. http://www.cdc.gov/niosh/npg/npgd0194.html. April 6, 2015.
NLM. 2015. TOXMAP:^®^ Environmental Health Maps. Superfund NPL. 1,1 Dichloroethene and ethylidene dichloride. U.S. National Library of Medicine, National Institutes of Health. http://toxmapclassic.nlm.nih.gov/toxmap/search/select.do#. April 2, 2015.
NOES. 1990. Estimated numbers of employees potentially exposed to specific agents by occupation. CAS #: 75–34-3. National Occupational Exposure Survey conducted from 1981 to 1983. National Occupational Exposure Survey. National Institute for Occupational Safety and Health. http://www.cdc.gov/noes/. May 11, 2015.
Nohmi T, Miyata R, Yoshikawa K, 1985. [Mutagenicity tests on organic chemical contaminants in city water and related compounds: I. Bacterial mutagenicity tests]. Bulletin of National Hygiene Science 103:60–64. (Japanese).
NRC. 1993. National Research Council. Pesticides in the diets of infants and children. Washington, DC: National Academy Press.
NTP. 2011. Report on carcinogens. 11^th^ ed. Research Triangle Park, NC: National Toxicology Program. U.S. Department of Health and Human Services, Public Health Service. http://ntp-server.niehs.nih.gov/ntp/roc/twelfth/roc12.pdf. April 25, 2012.
NTP. 2014. Report on carcinogens, thirteenth edition. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program. http://ntp.niehs.nih.gov/pubhealth/roc/roc13/. March 31, 2015.
Oliver KD, Adams JR, Daughtrey EHJ, 1996. Technique for monitoring toxic VOCs in air: Sorbent preconcentration, closed-cycle cooler cryofocusing, and GC analysis. Environ Sci Technol 30(6):1939–1945.
O'Neil MJ, Heckelman PE, Koch CB, , eds 2006. Ethylidene chloride. In: The Merck index. Whitehouse Station, N J: Merck & Co., Inc., 653.
OSHA. 2013. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Standards. Code of Federal Regulations 29 CFR 1910.1000. http://www.gpo.gov/fdsys/pkg/CFR-2014-title29-vol6/pdf/CFR-2014-title29-vol6-sec1910–1000.pdf. March 4, 2015.
OSHA. 2014a. Gases, vapors, fumes, dusts, and mists. Appendix A to 1926.55–1970. American Conference of Governmental Industrial Hygienists’ threshold limit values of airborne contaminants for construction. Subpart D-Occupational health and environmental controls. Occupational Safety and Health Standards. Code of Federal Regulations 29 CFR 1926.55. http://www.gpo.gov/fdsys/pkg/CFR-2014-title29-vol8/pdf/CFR-2014-title29-vol8-sec1926–55.pdf. March 4, 2015.
OSHA. 2014b. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z - Shipyards. Occupational Safety and Health Standards. Code of Federal Regulations 29 CFR 1915.1000. http://www.gpo.gov/fdsys/pkg/CFR-2013-title29-vol7/pdf/CFR-2013-title29-vol7-sec1915-1000.pdf. March 4, 2015.
Otson R, Chan C. 1987. Sample handling and analysis for 51 volatile organics by an adapted purge and trap GC-MS technique. Int J Environ A nal Chem 30:275–287.
Otson R, Williams DT. 1981. Evaluation of a liquid-liquid extraction technique for water pollutants. J Chromatogr 212:187–198.
Otson R, Williams DT. 1982. Headspace chromatographic determination of water pollutants. Anal Chem 54:942–946.
Owen GM, Brozek J. 1966. Influence of age, sex and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 222–238.
Page BD, LaCroix GM. 1995. On-line steam distillation/purge and trap analysis of halogenated, nonpolar, volatile contaminants in foods. J AOAC Int 78(6):1416–1428.8664577
Pankow JF, Rosen ME. 1988. Determination of volatile compounds in water by purging directly to a capillary column with whole column cryotrapping. Environ Sci Technol 22:398–405.
Parker JC, Casey GE, Bahlman LJ, 1979. Chloroethanes: Review of toxicity. Am Ind Hyg Assoc J 40:A46–A57.495456
Pearson CR, Mcconnell G. 1975. Chlorinated C_1_ and C_2_ hydrocarbons in the marine environment. Proc R Soc London 189:305–332.238199
Pellizzari ED. 1982. Analysis for organic vapor emissions near industrial and chemical waste disposal sites. Environ Sci Technol 16:781–785.22299786
Pellizzari ED, Erickson MC, Zweidinger RA. 1979. Formulation of preliminary assessment of halogenated organic compounds in man and environmental media. Washington, DC: U.S. Environmental Protection Agency. PB80112170
Perwak J, Byrne M, Goyer M, 1982. Exposure and risk assessment for dichloroethanes. 1,1-Dichloroethane, 1,2-dichloroethane. Washington, DC: U.S. Environmental Protection Agency, Office of Water Regulations and Standards. EPA440485009. PB85220564.
Plaa GL, Larson RE. 1965. Relative nephrotoxic properties of chlorinated methane, ethane, and ethylene derivatives in mice. Toxicol Appl Pharmacol 7:37–44.14256601
Plumb RH. 1987. A comparison of groundwater monitoring data from CERCLA and RCRA sites. Ground Water Monit Rev 7:94–100.
Raymer JH, Thomas KW, Cooper SD, 1990. A device for sampling of human alveolar breath for the measurement of expired volatile organic compounds. J Anal Toxicol 14(6):337–344.2128356
Reding R. 1987. Chromatographic monitoring methods for organic contaminants under the Safe Drinking Water Act. J Chromatogr Sci 25:338–344.
Reid JB, Muianga CV. 2012. Saturated halogenated aliphatic hydrocarbons two to four carbons. In: Bingham E, Cohrssen B, eds. Patty's industrial hygiene and toxicology. ed. 61–127. http://onlinelibrary.wiley.com/doi/10.1002/0471435139.tox063.pub2/abstract. October 4, 2012. 22349641
Reinert KH, Hunter JV, Sabatino T. 1983. Dynamic heated headspace analyses of volatile organic compounds present in fish tissue samples. J Agric Food Chem 31:1057–1060.
Riccio E, Griffin A, Mortelmans K, 1983. A comparative mutagenicity study of volatile halogenated hydrocarbons using different metabolic activation systems. Environ Mutagen 5:472.
Roose P, Brinkman UA. 1998. Determination of volatile organic compounds in marine biota. J Chromatogr A 799(1–2):233–248.
Sato A, Nakajima T. 1987. Pharmacokinetics of organic solvent vapors in relation to their toxicity. Scand J Work Environ Health 13:81–93.3299685
Sato A, Nakajima T, Koyama Y. 1980. Effects of chronic ethanol consumption on hepatic metabolism of aromatic and chlorinated hydrocarbons in rats. Br J Ind Med 37:382–386.7192567
Saunders NR, Ek CJ, Habgood MD, 2008. Barriers in the brain: A renaissance? Trends Neurosci 31(6):279–286. 10.1016/j.tins.2008.03.003. 18471905
Saunders NR, Liddelow SA, Dziegielewska KM. 2012. Barrier mechanisms in the developing brain. Front Pharmacol 3:Article 46. 10.3389/fphar.2012.00046.
Scheuplein R, Charnley G, Dourson M. 2002. Differential sensitivity of children and adults to chemical toxicity. I. Biological basis. Regul Toxicol Pharmacol 35(3):429–447.12202057
Schwetz BA, Leong BKJ, Gehring PJ. 1974. Embryo-and fetotoxicity of inhaled carbon tetrachloride, 1,1-dichloroethane and methyl ethyl ketone in rats. Toxicol Appl Pharmacol 28:452–464.4851838
Silgoner I, Rosenberg E, Grasserbauer M. 1997. Determination of volatile organic compounds in water by purge-and-trap gas chromatography coupled to atomic emission detection. J Chromatogr A 68(2):259–270.
Simmon VF, Kauhanen K, Tardiff RG. 1977. Mutagenic activity of chemicals identified in drinking water. Dev Toxicol Environ Sci 2:249–258.
Simpson G, Klasmeier M, Hill H, 1996. Evaluation of gas chromatography coupled with ion mobility spectrometry for monitoring vinyl chloride and other chlorinated and aromatic compounds in air samples. J High Resolut Chromatogr 19(6):301–312.
Singh HB, Salas LJ, Smith AJ, 1981. Measurements of some potentially hazardous organic chemicals in urban environments. Atmos Environ 15:601–612.
Smyth HF. 1956. Improved communication: Hygienic standards for daily inhalation. Am Ind Hyg Assoc Q 17:129–195.13326842
Spain MA, Middleditch BS, Bafus DA, 1985. Dehydrohalogenation of atmospheric contaminants in the space cabin. Aviat Space Environ Med 56:262–264.2859013
Spicer CW, Buxton B, Holdren MW, 1996. Variability of hazardous air pollutants in an urban area. Atmos Environ 30(20):3443–3456.
Squillace PJ, Moran MJ, Lapham WW, 1999. Volatile organic compounds in untreated ambient groundwater of the United States, 1985–1995. Environ Sci Technol 33(23):4176–4187.
SRI. 2011. 2011 Directory of chemical producers United States. SRI Consulting.
Staples CA, Werner A, Hoogheem TJ. 1985. Assessment of priority pollutant concentrations in the United States using STORET database. Environ Toxicol Chem 4:131–142.
Suffet IH, Brenner L, Cairo PR. 1980. Gas chromatography-mass spectrometry identification of trace organics in Philadelphia, Pennsylvania, USA, drinking waters during a 2-year period. Water Res 14:853–867.
Tabak HH, Quave SA, Mashni CI, 1981. Biodegradability studies with organic priority pollutant compounds. J Water Pollut Control Fed 53:1503–1518.
Thomas K, Colborn T. 1992. Organochlorine endocrine disruptors in human tissue. In: Colborn T, Clement C, eds. Chemically induced alterations in sexual and functional development: The wildlife/human connection. Princeton, NJ: Princeton Scientific Publishing, 365–394.
Tomasi A, Albano E, Bini A, 1984. Free radical intermediates under hypoxic conditions in the metabolism of halogenated carcinogens. Toxicol Pathol 12:240–246.6393297
TRI13. 2014. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Office of Information Analysis and Access. Office of Environmental Information. U.S. Environmental Protection Agency. Toxics Release Inventory. http://www.epa.gov/triexplorer/. November 12, 2014.
Tu AS, Murray T A, Hatch KM, 1985. In vitro transformation of BALB/c-3T3 cells by chlorinated ethanes and ethylenes. Cancer Lett 28:85–92.4027960
Uehori R, Nagata T, Kimura K, 1987. Screening of volatile compounds present in human blood using retention indices in gas chromatography. J Chromatogr 411:251–257.3443624
Ursova TP. 1953. [The possible presence of dichloroethane in human milk with exposure to industrial conditions]. Gig Sanit 18:36–37. (Russian)
USGS. 2003a. A national survey of methyl tert-butyl ether and other volatile organic compounds in drinking-water sources: Results of the random survey. U.S. Geological Survey. U.S. Department of the Interior.
USGS. 2003b. Quality and sources of shallow ground water in areas of recent residential development in Salt Lake Valley, Salt Lake Country, Utah. U.S. Geological Survery. Water-Resources Investigations Report 03–4028. http://pubs.usgs.gov/wri/wri034028/PDF/WRI034028.pdf. April 1, 2015.
USGS. 2006a. Volatile organic compounds in the nation's ground water and drinking-water supply wells. U.S. Geological Survey. U.S. Department of the Interior, National Water Quality Assessment Program.
USGS. 2006b. Investigation of contaminated ground-water at solid waste management Unit 12, Naval Weapons Station Charleston, North Charleston, South Carolina, 2006–2007. U.S. Geological Survey. U.S. Department of the Interior.
USGS. 2010a. An update of hydrologic conditions and distribution of selected constituents in water, Snake River Plain aquifer and perched groundwater zones, Idaho National Laboratory, Idaho, emphasis 2006–08. U.S. Geological Survey. U.S. Department of Energy. Scientific Investigations Report 2010–5197. http://pubs.er.usgs.gov/publication/sir20105197. April 1, 2015.
USGS. 2010b. Appendixes to quality of source water from public-supply wells in the United States, 1993–2007. Scientific Investigations Report 2010–5024. U.S. Geological Survey. Scientific Investigations Report 2010–5024. http://pubs.usgs.gov/sir/2010/5024/pdf/sir20105024_appendixes.pdf. April 1, 2015.
USGS. 2010c. Occurrence and distribution of organic chemicals and nutrients and comparison of water-quality data from public drinking-water supplies in the Columbia aquifer in Delaware, 2000–08. U.S. Geological Survey. Scientific Investigations Report 2010–5206. http://pubs.usgs.gov/sir/2010/5206/. April 1, 2015.
USGS. 2010d. Quality of source water from public-supply wells in the United States, 1993–2007. U.S. Geological Survey. Scientific Investigations Report 2010–5024. http://pubs.usgs.gov/sir/2010/5024/. April 1, 2015.
USGS. 2012. Assessment of soil-gas contamination at three former fuel-dispensing sites, Fort Gordon, Georgia, 2010–2011. U.S. Geological Survey. Open-File Report 2012–1082. http://pubs.usgs.gov/of/2012/1082/. April 1, 2015.
Van Dyke RA, Wineman CG. 1971. Enzymatic dechlorination: Dechlorination of chloroethanes and propanes in vitro. Biochem Pharmacol 20:463–470.4402457
van Eekert MH, Stams AJ, Field JA. 1999. Gratuitous dechlorination of chloroethanes by methanogenic granular sludge. Appl Microbiol Biotechnol 51(1):46–52.
Verschueren K. 1983. Handbook of environmental data on organic chemicals. 2nd ed. New York, NY: Van Nostrand Reinhold Co., 486.
Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238(2):476–483.8681961
Vogel TM, McCarty PL. 1987. Abiotic and biotic transformations of 1,1,1-trichloroethane under methanogenic conditions. Environ Sci Technol 21:1208–1213.
Wallace L, Zweidinger R, Erickson M, 1982. Monitoring individual exposure. Measurements of volatile organic compounds in breathing air, drinking water, and exhaled breath. Environ Int 8:269–282.
Wallace LA, Pellizzari E, Harwell T, 1984. Personal exposure to volatile organic compounds. I. Direct measurements. Environ Res 35:293–319.6489295
Wang B, Ho SSH, Ho KF, 2012. An environmental chamber study of the characteristics of air pollutants released from environmental tobacco smoke. Aerosol Air Qual Res 12(6):1269–1281. I 10.4209/aaqr.2011.11.0221.
Weiss G. 1986. Hazardous chemicals databook. 2nd ed. Park Ridge, NJ: Noyes Data Corporation, 359.
West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
Westrick JJ, Mello JW, Thomas RF. 1984. The groundwater supply survey. J Am Water Works Assoc 76:52–59.
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. September 9, 2014.
WHO. 2011. Guidelines for drinking-water quality. Geneva, Switzerland: World Health Organization. http://whqlibdoc.who.int/publications/2011/9789241548151_eng.pdf?ua=1. September 9, 2014.
Widdowson EM, Dickerson JWT. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advanced treatise. Volume II: The elements Part A. New York, NY: Academic Press, 1–247.
Wilson JT, McNabb JF, Wilson BH, 1983. Biotransformation of selected organic pollutants in groundwater. Dev Ind Microbiol 24:225–233.
Wilson JT, Enfield CG, Dunlap WJ, 1981. Transport and fate of selected organic pollutants in a sandy soil. J Environ Qual 10(4):501–506.
Witkowska D. 2013. Volatile gas concentrations in indoor turkey farms. Br Poult Sci 54(3):289–297. I 10.1080/00071668.2013.781264. 23638615
Wong PS, Cooks RG, Cisper ME, 1995. On-line in situ analysis with membrane introduction MS. A new analytical technique promises rapid environmental analyses for volatile organics in air and water. Environ Sci Technol 29(5):215A-218A.
Wood PR, Lang RF, Payan IL. 1985. Anaerobic transformation, transport, and removal of volatile chlorinated organics in ground water. In: Ward CH, Giger W, eds. Ground water quality. New York, NY: John Wiley and Sons, 493–511.
Wylie PL. 1988. Comparing headspace with purge and trap for analysis of volatile priority pollutants. J Am Water Works Assoc 80:65–72.
Yang RS, Rauckman EJ. 1987. Toxicological studies of chemical mixtures of environmental concern at the National Toxicology Program: health effects of groundwater contaminants. Toxicology 47:15–34.3686528
Young DR, Gossett RW, Baird RB, 1983. Wastewater inputs and marine bioaccumulation of priority pollutant organics off Southern California. Water Chlorination: Environmental Impact and Health Effects 4:871–884.
Ziegler EE, Edwards BB, Jensen RL, 1978. Absorption and retention of lead by infants. Pediatr Res 12(1):29–34.643372