# 8 REGULATIONS, ADVISORIES, AND GUIDELINES

MRLs are substance specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites.

No inhalation or oral MRLs were derived for 1,1-dichloroethane.

The EPA (IRIS 2002) has not derived an oral reference dose (RfD) or an inhalation reference concentration (RfC) for 1,1-dichloroethane.

1,1-Dichloroethane appears on the list of chemicals in “The Emergency Planning and Community Right-to-Know Act of 1986” and has been assigned a reportable quantity (RQ) limit of 1,000 pounds (EPA 2014e). The RQ represents the amount of a designated hazardous substance which, when released to any environmental media, must be reported to the appropriate authority.

The international and national regulations, advisories, and guidelines regarding 1,1-dichloroethane in air, water, and other media are summarized in Table 8-1.

Table 8-1 Regulations, Advisories, and Guidelines Applicable to 1,1-Dichloroethane

Agency | Description | Information | Reference
[underlined: INTERNATIONAL]
Guidelines:
IARC | Carcinogenicity classification | No data | IARC 2015
WHO | Air quality guidelines | No data | WHO 2010
| Drinking water quality guidelines | No data^a^ | WHO 2011
[underlined: NATIONAL]
Regulations and Guidelines:
a. Air
ACGIH | TLV (8-hour TWA) | 100 ppm | ACGIH 2014
AIHA | ERPGs | No data | AIHA 2014
DOE | PAC-1 and PAC-2^b^ | 160 ppm | DOE 2012a
| PAC-3^b^ | 4,000 ppm
EPA | AEGLs | No data | EPA 2014b
| NAAQS | No data | EPA 2012b
NIOSH | REL (10-hour TWA) | 100 ppm (400 mg/m^3^)^c^ | NIOSH 2015
| IDLH | 3,000 ppm
OSHA | PEL (8-hour TWA) for general industry | 100 ppm (400 mg/m^3^) | OSHA 2013; 29 CFR 1910.1000, Table Z-1
| PEL (8-hour TWA) for construction | 100 ppm (400 mg/m^3^) | OSHA 2014a; 29 CFR 1926.55, Appendix A
| PEL (8-hour TWA) for shipyards | 100 ppm (400 mg/m^3^) | OSHA 2014b; 29 CFR 1915.1000
b. Water
EPA | Designated as hazardous substances in accordance with Section 311(b)(2)(A) of the Clean Water Act | No data | EPA 2013a; 40 CFR 116.4
| Drinking water standards and health advisories | No data | EPA 2012a
| Master Testing List | Yes^d^ | EPA 2014c
| National primary drinking water standards | No data | EPA 2009
| National recommended water quality criteria: human health for the consumption of | No data | EPA 2013b
| Reportable quantities of hazardous substances designated pursuant to Section 311 of the Clean Water Act | No data | EPA 2013c; 40 CFR 117.3
c. Food
FDA | EAFUS^e^ | No data | FDA 2013
d. Other
ACGIH | Carcinogenicity classification | A4^f^ | ACGIH 2014
EPA | Carcinogenicity classification | C^g^ | IRIS 2002
| RfC | No data
| RfD | No data
| Identification and listing of hazardous waster | U076 | EPA 2013e; 40 CFR 261, Appendix VIII
| Inert pesticide ingredients in pesticide products | No data | EPA 2014d
| Superfund, emergency planning, and community right-to-know
| Designated CERCLA hazardous substance and reportable quantity | 1,000 pounds^h^ | EPA 2014e; 40 CFR 302.4
| Effective date of toxic chemical release reporting | 01/01/1994 | EPA 2014f; 40 CFR 372.65
| Extremely hazardous substances and its threshold planning quantity | No data | EPA 2013d; 40 CFR 355, Appendix A
| TSCA chemical lists and reporting periods | | EPA 2014g; 40 CFR 712.30
| Effective date | 03/11/1994
| Reporting date | 05/10/1994
| TSCA health and safety data reporting | | EPA 2014h; 40 CFR 716.120
| Effective date | 06/01/1987 | EPA 2014h; 40 CFR 716.120
| Reporting date | 06/01/1997
NTP | Carcinogenicity classification | No data | NTP 2014

a In view of the very limited database on toxicity and carcinogenicity, the Guidelines concluded that no guideline value for 1,1-dichloroethane should be proposed.

b Definitions of PAC terminology are available from U.S. Department of Energy (DOE 2012b).

c NIOSH recommends that 1,1-dichloroethane be treated in the workplace with caution because of its structural similarity to the four chloroethanes (ethylene dichloride, hexachloroethane, 1,1,2,2-tetrachloroethane, and 1,1,2-trichloroethane) shown to be carcinogenic in animals.

d 1,-Dichloroethane was recommended to the MTL by the EPA’s Office of Water and Office of Drinking Water in 1990 and was later removed in 1995. The initial chemical testing program was for prechronic toxicity (14–28 day) and subchronic toxicity (90 day) health effects.

e The EAFUS list of substances contains ingredients added directly to food that FDA has either approved as food additives or listed or affirmed as GRAS.

f A4: not classifiable as a human carcinogen

g C: possible human carcinogen

h Designated CERCLA hazardous substance pursuant to Section 307(a)of the Clean Water Act, Section 112 of the Clean Air Act, and Section 3001 of RCRA.

ACGIH = American Conference of Governmental Industrial Hygienists; AEGL = acute exposure guideline levels; AIHA = American Industrial Hygiene Association; CERCLA = Comprehensive Environmental Response, Compensation, and Liability Act; CFR = Code of Federal Regulations; DOE = Department of Energy; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; ERPG = emergency response planning guidelines; FDA = Food and Drug Administration; GRAS = Generally Recognized As Safe; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; MTL = Master Testing List; NAAQS = National Ambient Air Quality Standards; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = Protective Action Criteria; PEL = permissible exposure limit; RCRA = Resource Conservation and Recovery Act; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TLV = threshold limit values; TSCA = Toxic Substances Control Act; TSD = treatment, storage, and disposal; TWA = time-weighted average; WHO = World Health Organization