# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

The synonyms, and identification numbers for 1,1-dichloroethane are listed in Table 4-1.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Important physical and chemical properties of 1,1-dichloroethane are listed in Table 4-2.

Table 4-1 Chemical Identity of 1,1-Dichloroethane

Characteristic | Information^a^ | Reference
Chemical name | 1,1-Dichloroethane^b^
Synonym(s) | Alpha,alpha-dichloroethane; asymmetrical dichloroethane; S-dichloroethene; Dutch oil; ethane, 1,1-dichloro-; ethylidene chloride; ethylidene dichloride; 1,1-ethylidene dichloride^c^
Registered trade name(s) | No data
Chemical formula | C2H4Cl2^b^
Chemical structure | [image]
Identification numbers:
CAS registry | 75-34-3^b^
NIOSH RTECS | KI0175000
EPA hazardous waste | U076
OHM/TADS | No data
DOT/UN/NA/IMDG shipping | DOT 2362; UN 2362; IMO 3.2
HSDB | 64
NCI | C04535^d^

a All information obtained from HSDB 2012, except where noted

b O’Neil et al. 2006

c Archer 1978; Weiss 1986

d ChemIDPlus Lite 2012

CAS = Chemical Abstracts Service; DOT/UN/NA/IMDG = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of 1,1-Dichloroethane

Property | Information | Reference
Molecular weight | 98.97 | HSDB 2012
Color | Colorless
Physical state | Oily liquid | O’Neil et al. 2006
Melting point | −96.9 °C | HSDB 2012
Boiling point | 57.3 °C | O’Neil et al. 2006
Density at 20 °C | 1.175 g/cm^3^ | HSDB 2012
Odor | Aromatic ethereal; chloroform-like
Odor threshold:
Water | No data
Air | 120 ppm; 200 ppm | Verschueren 1983
Solubility:
Water at 20 °C | 0.55 g/100 g | HSDB 2012
Organic solvents | Miscible with oxygenated and chlorinated solvents
Partition coefficients:
Log K_ow_ | 1.79 | HSDB 2012
Log K_oc_ | 1.48 | HSDB 2012
Vapor pressure at 25 °C | 230 mmHg | HSDB 2012
Henry’s law constant at 24 °C | 5.62×10^−3^ atm-m^3^/mol; 5.51×10^−3^ atm-m^3^/mol | HSDB 2012; Chen et al. 2012
Autoignition temperature | 457.8 °C | HSDB 2012
Flashpoint | Closed cup −12 °C; open cup 14 °C | HSDB 2012
Flammability limits | Lower 5.4%; upper 11.4% | HSDB 2012
Conversion factors | 1 ppm × 4.05 = 1 mg/m^3^; 1 mg/m^3^ × 0.25 = 1 ppm
Explosive limits | Lower explosive limit: 5.6%; moderate explosion hazard when exposed to heat or flame | HSDB 2012