# CHAPTER 8 REFERENCES

AAMRL. 1987. Evaluation of the acute toxicity of selected groundwater contaminants. Wright-Patterson Air Force Base, OH: Harry G. Armstrong Aerospace Medical Research Laboratory, Air Force Systems Command. 10. AAMRL-TR-87–021. ADA180198. https://apps.dtic.mil/sti/citations/ADA180198. September 27, 2023.
Abe T, Wakui C. 1984. [Necessity for total trichloride compound measurement in screening tests for workers exposed to trichloroethylene or 1,1,1,-trichloroethane]. Sangyo Igaku 26(6):492–499. 10.1539/joh1959.26.492. (Japanese)6242169
Adams EM, Spencer HC, Rowe KV, 1950. Vapor toxicity of 1,1,1-trichloroethane (methylchloroform) determined by experiments on laboratory animals. Arch Ind Hyg Occup Med 1(2):225–236.15426339
Adinolfi M. 1985. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol 27(4):532–537. 10.1111/j.1469-8749.1985.tb04581.x.4029526
Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect 103(Suppl 7):103–112. 10.1289/ehp.95103s7103.
Aitio A, Pekari K, Järvisalo J. 1984. Skin absorption as a source of error in biological monitoring. Scand J Work Environ Health 10(5):317–320. 10.5271/sjweh.2323.6523096
Al-Griw MA, Treesh SA, Alghazeer RO, 2017. Environmentally toxicant exposures induced intragenerational transmission of liver abnormalities in mice. Open Vet J 7(3):244–253. 10.4314/ovj.v7i3.8.28884077
Alles G, Bauer U, Selenka F. 1988. [Volatile organochlorine compounds in human tissue]. Zentralbl Bakteriol Mikrobiol Hyg B Umwelthyg Krankenhaushyg Arbeitshyg Prav Med 186:233–246. (German)3138840
Althaus FR, Lawrence SD, Sattler GL, 1982. Chemical quantification of unscheduled DNA synthesis in cultured hepatocytes as an assay for the rapid screening of potential chemical carcinogens. Cancer Res 42:3010–3015.7093950
Amoore JE, Hautala E. 1983. Odor as an air to chemical safety: Odor thresholds compared with threshold limit values and volatilities for 214 industrial chemicals in air and water dilution. J Appl Toxicol 3(6):272–290.6376602
Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York, NY: Marcel Dekker, Inc., 9–25.
Andersson-Skold Y, Grennfelt P, Pleijel K. 1992. Photochemical ozone creation potentials. A study of different concepts. J Air Waste Manage Assoc 42(9):1152–1158.
Anttila A, Pukkala E, Sallmen M, 1995. Cancer incidence among Finnish workers exposed to halogenated hydrocarbons. J Occup Environ Med 37(7):797–806. 10.1097/00043764-199507000-00008.7552463
Aranyi C, O'Shea WJ, Graham JA, 1986. The effects of inhalation of organic chemical air contaminants on murine lung host defenses. Fundam Appl Toxicol 6:713–720. 10.1016/0272-0590(86)90184-3.3519345
Arthur CL, Pratt K, Motlagh S, 1992. Environmental analysis of organic compounds in water using solid phase micro extraction. J High Resolut Chromatogr 15:741–744.
Arvin E. 1991. Biodegradation kinetics of chlorinated aliphatic hydrocarbons with methane oxidizing bacteria in an aerobic fixed biofilm reactor. Water Res 25(7):873–881.
Astrand I, Kilbom A, Wahlberg I, 1973. Methylchloroform exposure: I. Concentration in alveolar air and blood at rest and during exercise. Scand J Work Environ Health 10:69–81.
Atkinson R. 1985. Kinetics and mechanisms of the gas-phase reactions of hydroxyl radical with organic compounds under atmospheric conditions. Chem Rev 85(1):69–201.
ATSDR. 1988. Health assessment for Vestal Water Supply Well 1–1, Town of Vestal, New York, Region 2. CERCLIS No. NYD980763767. Atlanta, GA: Agency for Toxic Substances and Disease Registry. PB90140062.
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles. Agency for Toxic Substances and Disease Registry. Federal Register 54(174):37618–37634.
ATSDR. 2004. Interaction profile for: 1,1,1-Trichloroethane, 1,1-dichloroethane, trichloroethylene, and tetrachloroethylene. Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/interactionprofiles/ip02.html. September 27, 2023.
ATSDR. 2005a. Health consultation. Outokumpu/former Uptown Brass Redeveloment Project (a/k/a Kenosha City - former Outokumpu site). Kenosha, Kenosha County, Wisconsin EPA facility ID: WID006101695. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
ATSDR. 2005b. Health consultation: Van Waters & Rogers site. City of Minneapolis, Hennepin County, Minnesota. EPA facility ID: MND054497052. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
ATSDR. 2006. Public health assessment for Valmont TCE Site: formerly Valmont Industrial Park site (a/k/a Valmont Industrial Park). West Hazelton, Luzerne County, Pennsylvania. EPA facility ID: PAD982363970. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
ATSDR. 2022. 1,1,1-Trichloroethane. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/SPL/resources/index.html. June 24, 2022.
ATSDR. 2023. Sanders2015 HLCs used in SHOWER Model v3 and PHAST. Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/pha-guidance/toolbox/ATSDR_SHOWER_Model_v3_0_0.zip. August 17, 2023.
Baker RS U, Bonin AM. 1981. Study of 42 coded compounds with the Salmonella/mammalian microsome assay. Prog Mutat Res 1:249–260.
Balster RL, Moser VC, Woolverton WL. 1982. Concurrent measurement of solvent vapor concentrations and effects on operant behavior using a dynamic exposure system. J Pharmacol Methods 8:299–309. 10.1016/0160-5402(82)90047-x.7154680
Balster RL, Bowen SE, Evans EB, 1997. Evaluation of the acute behavioral effects and abuse potential of a C8-C9 isoparaffin solvent. Drug Alcohol Depend 46(3):125–135. 10.1016/s0376-8716(97)00055-0.9250471
Barker JF. 1987. Volatile aromatic and chlorinated organic contaminants in groundwater at six Ontario landfills. Water Pollut Res J Canada 22:33–48.
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
Barrows ME, Petrocelli SR, Macek KJ, 1980. Bioconcentration and elimination of selected water pollutants by bluegill sunfish (Lepomis macrochirus). In: Hague R, ed. Dynamics, exposure and hazard assessment of toxic chemicals. Ann Arbor, MI: Ann Arbor Science, 379–392.
Bass M. 1970. Sudden sniffing death. J Am Med Assoc 212(12):2075–2079.
Benson EN, Hunter JV. 1976. Comparative effects of halogenated hydrocarbon solvents on waste disposal processes. In: 31st Industrial Waste Conference. Purdue University, Lafayette, Indiana: Ann Arbor Science Publishers, 614–637.
Berode M, Boillat MA, Guillemin MP, 1990. Demethylation pathways in caffeine metabolism as indicators of variability in 1,1,1-trichloroethane oxidation in man. Pharmacol Toxicol 67(1):41–46. 10.1111/j.1600-0773.1990.tb00779.x.2395815
Bogen KT, Hall LC. 1989. Pharmacokinetics for regulatory risk analysis: The case of 1,1,1-trichloroethane (methyl chloroform). Regul Toxicol Pharmacol 10:26–50.2672126
Boman A, Mellstrom G. 1989. Percutaneous absorption of 3 organic solvents in the guinea pig (IV). Effect of protective gloves. Contact Dermatitis 21(4):260–266. 10.1111/j.1600-0536.1989.tb03206.x.2598653
Boman A, Wahlberg JE. 1989. Percutaneous absorption of 3 organic solvents in the guinea pig (I): Effect of physical and chemical injuries to the skin. Contact Dermatitis 21(1):36–45. 10.1111/j.1600-0536.1989.tb04682.x.2805658
Bonnet P, Francin JM, Gradiski D, 1980. [Determination of the LC_50_ of the principle chlorinated aliphatic hydrocarbons in the rat]. Arch Mal Prof 41(6–7):317–321. (French)
Boogaard PJ, Hays SM, Aylward LL. 2011. Human biomonitoring as a pragmatic tool to support health risk management of chemicals--examples under the EU REACH Programme. Regul Toxicol Pharmacol 59(1):125–132. 10.1016/j.yrtph.2010.09.015.20933039
Bouwer EJ, McCarty PL. 1983a. Transformation of halogenated organic compounds under denitrification conditions. Appl Environ Microbiol 45(4):1295–1299.6859850
Bouwer EJ, McCarty PL. 1983b. Transformation of 1- and 2-carbon halogenated aliphatic organic compounds under methanogenic conditions. Appl Environ Microbiol 45(4):1286–1294.6859849
Bouwer EJ, McCarty PL. 1984. Modeling of trace organics biotransformation in the subsurface. Ground Water 22:433–440.
Bove FJ, Fulcomer MC, Klotz JB, 1995. Public drinking water contamination and birth outcomes. Am J Epidemiol 141(9):850–862. 10.1093/oxfordjournals.aje.a117521.7717362
Bowen SE, Balster RL. 1996. Effects of inhaled 1,1,1-trichloroethane on locomotor activity in mice. Neurotoxicol Teratol 18(1):77–81. 10.1016/0892-0362(95)02024-1.8700046
Bowen SE, Balster RL. 1998. A direct comparison of inhalant effects on locomotor activity and schedule-controlled behavior in mice. Exp Clin Pyschopharmacol 6(3):235–247. 10.1037//1064-1297.6.3.235.
Bowen SE, Balster RL. 2006. Tolerance and sensitization to inhaled 1,1,1-trichloroethane in mice: results from open-field behavior and a functional observational battery. Psychopharmacology 185(4):405–415. 10.1007/s00213-006-0335-1.16541244
Bowen SE, Wiley JL, Balster RL. 1996a. The effects of abused inhalants on mouse behavior in an elevated plus-maze. Eur J Pharmacol 312(2):131–136. 10.1016/0014-2999(96)00459-1.8894586
Bowen SE, Wiley JL, Evans EB, 1996b. Functional observational battery comparing effects of ethanol, 1,1,1-trichloroethane, ether, and flurothyl. Neurotoxicol Teratol 18(5):577–585. 10.1016/0892-0362(96)00064-5.8888022
Brahmachari S, Fung YK, Pahan K. 2006. Induction of glial fibrillary acidic protein expression in astrocytes by nitric oxide. J Neurosci 26(18):4930–4939. 10.1523/jneurosci.5480-05.2006.16672668
Brennan RJ, Schiestl RH. 1998. Chloroform and carbon tetrachloride induce intrachromosomal recombination and oxidative free radicals in Saccharomyces cerevisiae. Mutat Res 397:271–278.9541652
Brenner D. 2010. Results of a long-term study of vapor intrusion at four large buildings at the NASA Ames Research Center. J Air Waste Manag Assoc 60(6):747–758. 10.3155/1047-3289.60.6.747.20565001
Broholm K, Christensen TH, Jensen BK. 1991. Laboratory feasibility studies on biological in-situ treatment of a sandy soil contaminated with chlorinated aliphatics. Environ Toxicol 12:279–289.
Brooks TM, Dean BJ. 1981. Mutagenic activity of 42 coded compounds in the Salmonella/microsome assay with preincubation. Prog Mutat Res 1:261–270.
BRRC. 1987a. Developmental toxicity study of inhaled 1,1,1-trichloroethane in CD (Sprague-Dawley) rats. Letter from HSIA to US EPA regarding submission of final reports on developmental toxicity studies of 1,1,1-trichloroethane with attachments. Bushy Run Research Center. Submitted to U.S. Environmental Protection Agency under TSCA section 4. OTS0526509. 40–8724497. J3C-2. Project report 50–517.
BRRC. 1987b. Developmental toxicity study of inhaled 1,1,1-trichloroethane in New Zealand white rabbits. Letter from HSIA to US EPA regarding submission of final reports on developmental toxicity studies of 1,1,1-trichloroethane with attachments. Bushy Run Research Center. Submitted to U.S. Environmental Protection Agency under TSCA section 4. OTS0526509. 40–8724497. J3C-2. Project report 50–514.
Bruckner JV. 1983. Personal communication to: Paul T. McCauley; re: Findings of toxicological studies of 1,1,1-trichloroethane. Progress report on U.S. EPA Cooperative Agreement 807449.
Bruckner JV, Kyle GM, Luthra R, 2001. Acute, short-term and subchronic oral toxicity of 1,1,1-trichloroethane in rats. Toxicol Sci 60:363–372.11248149
Buchardt O, Manscher OH. 1980. On photochemical degradation of methylchloroform under atmospheric conditions. In: Second environmental research programme, 1976–80, indirect action: Reports on research sponsored under the second phase, 1979–80. Luxemburg: Commission of the European Communities, 17–22.
Burk T, Zarus G. 2013. Community exposures to chemicals through vapor intrusion: A review of past ATSDR public health evaluations. J Environ Health 75(9):36–41.
Calafat AM, Kuklenyik Z, Caudill SP, 2003. Urinary levels of trichloroacetic acid, a disinfection by-product in chlorinated drinking water, in a human reference population. Environ Health Perspect 111(2):151–154. 10.1289/ehp.5644.12573897
Calhoun LL, Quast JF, Schumann AM, 1981. Chloroethene VG: Preliminary studies to establish exposure concentrations for a chronic inhalation study with rats and mice. Midland, MI: Health and Environmental Sciences, The Dow Chemical Company.
Caperos JR, Droz PO, Hake CL, 1982. 1,1,1-Trichloroethane exposure, biologic monitoring by breath and urine analyses. Int Arch Occup Environ Health 49:293–303.7068241
Caplan YH, Backer RC, Whitaker JQ. 1976. 1,1,1-Trichloroethane: Report of a fatal intoxication. Clin Toxicol 9(1):69–74.1277770
CARB. 1992. Study of emissions and control of stratospheric ozone-depleting compounds in California. Sacramento, CA: California Air Resources Board. PB93160752. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB93160752.xhtml. September 27, 2023.
Carlson GP. 1973. Effect of phenobarbital and 3-methylcholanthrene pretreatment on the hepatotoxicity of 1,1,1-trichloroethane and 1,1,2-trichloroethane. Life Sci 13:67–73. 10.1016/0024-3205(73)90278-6.4356632
Carlson GP. 1981. Effect of alterations in drug metabolism on epinephrine-induced cardiac arrhythmias in rabbits exposed to methylchloroform. Toxicol Lett 9:307–313.7330895
Carroll GJ, Thurnau RC, Lee JW, 1992. Pilot-scale evaluation of an incinerability ranking system for hazardous organic compounds. J Air Waste Manage Assoc 42:1430–1436.
Casciola LA F, Ivanetich KM. 1984. Metabolism of chloroethanes by rat liver nuclear cytochrome P-450. Carcinogenesis 5(5):543–548.6722974
CDC. 2018. National Health and Nutrition Examination Survey. 2015–2016 data documentation, codebook, and frequencies. Volatile organic compounds and trihalomethanes/MTBE - Blood (VOCWB_I). Centers for Disease Control and Prevention. https://wwwn.cdc.gov/Nchs/Nhanes/2015-2016/VOCWB_I.htm. March 1, 2021.
CDC. 2022. Blood 1,1,1-trichloroethane (methyl chloroform) (2011 – 2018). National report on human exposure to environmental chemicals. Centers for Disease Control and Prevention. https://www.cdc.gov/exposurereport/data_tables.html. September 27, 2023.
CDR. 2012. Chemical data reporting. U.S. Environmental Protection Agency. https://www.epa.gov/chemical-data-reporting/access-cdr-data. February 18, 2021.
CDR. 2016. Chemical data reporting. U.S. Environmental Protection Agency. https://www.epa.gov/chemical-data-reporting/access-cdr-data. February 18, 2021.
CDR. 2020. Chemical data reporting. U.S. Environmental Protection Agency. https://www.epa.gov/chemical-data-reporting/access-cdr-data. date.
Chang EE, Wang W, Zeng L, 2010. Health risk assessment of exposure to selected volatile organic compounds emitted from an integrated iron and steel plant. Inhal Toxicol 22(S2):117–125. 10.3109/08958378.2010.507636.
Chen CC, Wu KY, Chang MJ W. 2004. A statistical assessment on the stochastic relationship between biomarker concentrations and environmental exposures. Stochastic Environ Res Risk Assess 18(6):377–385. 10.1007/s00477-004-0208-2.
Cherry N, Venables H, Waldron HA. 1983. The acute behavioral effects of solvent exposure. J Soc Occup Med 33:13–18.6827812
Cheung HM, Bhatnagar A, Jansen G. 1991. Sonochemical destruction of chlorinated hydrocarbons in dilute aqueous solution. Environ Sci Technol 25:1510–1512.
Chiou CT, Peters LJ, Freed VH. 1979. A physical concept of soil-water equilibria for nonionic organic compounds. Science 206:831–832.17820762
Chiou CT, Freed VH, Peters LJ, 1980. Evaporation of solutes from water. Environ Int 3:231–236.
Chiu WA, White P. 2006. Steady-state solutions to PBPK models and their applications to risk assessment I: Route-to-route extrapolation of volatile chemicals. Risk Anal 26(3):769–780. 10.1111/j.1539-6924.2006.00762.x.16834633
Ciccioli P, Brancaleoni E, Cecinato A, 1993. Identification and determination of biogenic and anthropogenic volatile organic compounds in forest areas of Northern and Southern Europe and a remote site of the Himalaya region by high-resolution gas chromatography-mass spectrometry. J Chromatogr 643:55–69.
Clark DG, Tinston DJ. 1973. Correlation of the cardiac sensitizing potential of halogenated hydrocarbons with their physicochemical properties. Br J Pharmacol 49:355–357.4793336
Clark DG, Tinston DJ. 1982. Acute inhalation toxicity of some halogenated and nonhalogenated hydrocarbons. Hum Toxicol 1:239–247.7173904
Class T, Ballschmiter K. 1986. Chemistry of organic traces in air. VI: Distribution of chlorinated C1C4 hydrocarbons in air over the northern and southern Atlantic Ocean. Chemosphere 15(4):413–427.
Clewell HJ. 1995. The application of physiologically based pharmacokinetic modeling in human health risk assessment of hazardous substances. Toxicol Lett 79(1–3):207–217. 10.1016/0378-4274(95)03372-r.7570658
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
CMR. 1992. Chemical profile: Trichloroethylene. Chem Market Rep. February 3, 1992
Cobb GD, Bouwer EJ. 1991. Effects of electron acceptors on halogenated organic compound biotransformations in a biofilm column. Environ Sci Technol 25:1068–1074.
Cohen C, Frank AL. 1994. Liver disease following occupational exposure to 1,1,1-trichloroethane: A case report. Am J Ind Med 26:237–241.7977399
Cole RH, Frederick RE, Healy RP, 1984. Preliminary findings of the priority pollutant monitoring project of the Nationwide Urban Runoff Program. J Water Pollut Control Fed 56(7):898–908.
Coleman CN, Mason T, Hooker EP, 1999. Developmental effects of intermittent prenatal exposure to 1,1,1-trichloroethane in the rat. Neurotoxicol Teratol 21(6):699–708.10560777
Comba ME, Kaiser KL E. 1985. Volatile halocarbons in the Detroit River and their relationship with contaminant sources. J Great Lakes Res 11(3):404–418.
Commission of the European Communities. 1981. Criteria (exposure/effect relationships) for organochlorine pesticides. In: Criteria (dose/effect relationships) for organochlorine pesticides. Pergamon Press,
Connell DW, Braddock RD, Mani SV. 1993. Prediction of the partition coefficient of lipophilic compounds in the air-mammal tissue system. Sci Total Environ (Suppl Pt 2):1383–1396. 10.1016/s0048-9697(05)80144-5.
Cornish HH, Adefuin J. 1966. Ethanol potentiation of halogenated aliphatic solvent toxicity. Am Ind Hyg Assoc J 27:57–61. 10.1080/00028896609342793.5920489
Cornish HH, Ling BP, Barth ML. 1973. Phenobarbital and organic solvent toxicity. Am Ind Hyg Assoc J 34:487–492.4770171
Corsi RL, Chang DP Y, Schroeder ED, 1987. Emissions of volatile and potentially toxic organic compounds from municipal wastewater treatment plants. In: Air Pollution Control Association Annual Meeting. Vol. 6. New York, NY: 1–14.
Crebelli R, Carere A. 1988. Genotoxic activity of halogenated aliphatic hydrocarbons in Aspergillus nidulans. J Occup Toxicol 8:437–442.
Crebelli R, Benigni R, Franekic J, 1988. Induction of chromosome malsegregation by halogenated organic solvents in Aspergillus nidulans: Unspecific or specific mechanism? Mutat Res 201:401–411.3050490
Croquet V, Fort J, Oberti F, 2003. [1,1,1-Trichloroethane-induced chronic active hepatitis]. Gastroenterol Clin Biol 27:120–122. (French)12594376
Crutzen PJ, Isaksen IS A, McAfee JR. 1978. The impact of the chlorocarbon industry on the ozone layer. J Geophys Res 83:345–363.
Dallas CE, Ramanathan R, Muralidhara S, 1989. The uptake and elimination of 1,1,1-trichloroethane during and following inhalation exposures in rats. Toxicol Appl Pharmacol 98:385–397.2718170
Daniel MR, Dehnel JM. 1981. Cell transformation test with baby hamster kidney cells. Prog Mutat Res 1:626–637.
Danielsson BR G, Ghantous H, Dencker L. 1986. Distribution of chloroform and methylchloroform and their metabolites in pregnant mice. Biol Res Pregnancy Perinatol 7(2):77–83.3730475
D'Costa DF, Gunasekera NP R. 1990. Fatal cerebral edema following trichloroethane abuse. J R Soc Med 83:533–534.2231588
De Ceaurriz J, Bonnet P, Certin C, 1981. [Chemicals as central nervous system depressants. Benefits of an animal model]. Cah Notes Doc 104(3):351–355. (French)
De Ceaurriz J, Desiles JP, Bonnet P, 1983. Concentration-dependent behavioral changes in mice following short-term inhalation exposure to various industrial solvents. Toxicol Appl Pharmacol 67(3):383–389. 10.1016/0041-008x(83)90322-8.6845368
Deane M, Swan SH, Harris JA, 1989. Adverse pregnancy outcomes in relation to water contamination, Santa Clara County, California, 1980–1981. Am J Epidemiol 129(5):894–904.2705433
DeJongh J, Verhaar HJ, Hermens JL. 1998. Role of kinetics in acute lethality of nonreactive volatile organic compounds (VOCs). Toxicol Sci 45(1):26–32. 10.1006/toxs.1998.2496.9848107
del Amo M, Berenguer J, Pujol T, 1996. MR in trichloroethane poisoning. AJNR Am J Neuroradiol 17:1180–1182.8791934
DeMore WB. 1992. Relative rate constants for the reactions of OH with methane and methyl chloroform. Geophys Res Lett 19(13):1367–1370.
Derwent RG, Jenkin ME. 1991. Hydrocarbons and the long-range transport of ozone and PAN across Europe. Atmos Environ 25(8):1661–1678.
Dever RJ. 1986. Responding to industrial contamination of groundwater: A case study. J Amer Water Works Assoc 78:82–86.
Dilling WL. 1977. Interphase transfer processes. II. Evaporation rates of chloromethanes, ethanes, ethylenes, propanes, and propylenes from dilute aqueous solutions: Comparisons with theoretical predictions. Environ Sci Technol 11(4):405–409.
Dilling WL, Tefertiller NB, Kallos GJ. 1975. Evaporation rates and reactivities of methylene chloride, chloroform, 1,1,1-trichloroethane, trichloroethylene, tetrachloroethylene and other chlorinated compounds in dilute aqueous solutions. Environ Sci Technol 9(9):833–888.
Dilling WL, Bredeweg CJ, Tefertiller NB. 1976. Organic photochemistry. XIII. Simulated atmospheric photodecomposition rates of methylene chloride, 1,1,1-trichloroethane, trichloroethylene, tetrachloroethylene, and other compounds. Environ Sci Technol 10:351–356.
Dimitriades B, Joshi S. 1977. Application of reactivity criteria in oxidant-related emission control in the USA. In: Dimitriades B, ed. Photochemical oxidant pollution and its control, international conference. Research Triangle Park, NC: U.S. Environmental Protection Agency, 705–711.
Ding C, Zhao S, He J. 2014. A Desulfitobacterium sp. strain PR reductively dechlorinates both 1,1,1-trichloroethane and chloroform. Environ Microbiol 16(11):3387–3397. 10.1111/1462-2920.12387.24428759
DiRenzo AB, Gandolfi AJ, Sipes IG. 1982. Microsomal bioactivation and covalent binding of aliphatic halides to DNA. Toxicol Lett 11:243–252.7101318
Dobrev ID, Andersen ME, Yang RS H. 2001. Assessing interaction thresholds for trichloroethylene in combination with tetrachloroethylene and 1,1,1-trichloroethane using gas uptake studies and PBPK modeling. Arch Toxicol 75(3):134–144. 10.1007/s002040100216.11409535
Dobrev ID, Andersen ME, Yang RS H. 2002. In silico toxicology: Simulating interaction thresholds for human exposure to mixtures of trichloroethylene, tetrachloroethylene, and 1,1,1-trichloroethane. Environ Health Perspect 110(10):1031–1039. 10.1289/ehp.021101031.
DOE. 2000. Trichloroethane, 1,1,1-; (methyl chloroform). PAC Database. U.S. Department of Energy. https://pacteels.pnnl.gov/. September 18, 2023.
DOE. 2023. Definition of PACs. U.S. Department of Energy. https://pacteels.pnnl.gov/#/definitions. September 18, 2023.
Doherty RE. 2000. A history of the production and use of carbon tetrachloride, tetrachloroethylene, trichloroethylene and 1,1,1-trichloroethane in the United States: Part 2 - trichloroethylene and 1,1,1-trichloroethane. J Environ Forensics 1(2):83–93. 10.1006/enfo.2000.0011.
Dosemeci M, Cocco P, Chow W. 1999. Gender differences in risk of renal cell carcinoma and occupational exposures to chlorinated aliphatic hydrocarbons. Am J Ind Med 36:54–59.10361587
Dow Chemical. 1990. Acute neurophysiologic effects of 1,1,1-trichloroethane via gavage in rats. Final report. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS533134.
Dow Chemical. 1993. Examination of rats for developmental neurotoxicological effects from maternal exposure to 1,1,1-trichloroethane. [Peer reviewed unpublished study]. Dow Chemical Company. Submitted in support of the 1,1,1-trichlorethane testing consent order. Docket No OPTS-42059C: Validation of a motor activity system in rats.
Dow Corning Corp. 1994. Initial submission: Epidemiology (population-based case-control) study of systemic sclerosis associated with silicone breast implants and solvents with cover letter dated 060394. Dow Corning Corporation. Submitted to U.S. Environmental Protection Agency under TSCA Section 8E. OTS0556275. 88–94000017. 8EHQ-0694–13075.
Droz PO, Fernandez JG. 1977. Effect of physical workload on retention and metabolism of inhaled organic solvents. A comparative theoretical approach and its applications with regards to exposure monitoring. Int Arch Occup Environ Health 38(4):231–246. 10.1007/BF00378335.838508
Droz PO, Nicole C, Guberan E. 1982. Sniffing 1,1,1-trichloroethane simulation of two fatal cases. In: Collings AJ, Luxon SG, eds. International Symposium on the safe use of solvents. University of Sussex, Brighton, UK: Academic Press, Inc., 153–159.
Droz PO, Wu MM, Cumberland WG. 1989a. Variability in biological monitoring of organic solvent exposure. II. Application of a population physiological model. Br J Ind Med 46(8):547–558. 10.1136/oem.46.8.547.2775674
Droz PO, Krebs Y, Nicole C, 1988. A direct reading method for chlorinated hydrocarbons in breath. Am Ind Hyg Assoc J 49(7):319–324. 10.1080/15298668891379837.3407591
Droz PO, Wu MM, Cumberland WG, 1989b. Variability in biological monitoring of solvent exposure. I. Development of a population physiological model. Br J Ind Med 46(7):447–460. 10.1136/oem.46.7.447.2765418
Durk H, Poyer JL, Klessen C, 1992. Acetylene, a mammalian metabolite of 1,1,1-trichloroethane. Biochem J 286:353–356.1326938
Eben A, Kimmerle G. 1974. Metabolism, excretion and toxicology of methylchloroform in acute and subacute exposed rats. Arch Toxicol 31(3):233–242. 10.1007/BF00311056.
Egle JL, Long JE, Simon GS, 1976. An evaluation of the cardiac sensitizing potential of a fabric protector in aerosol form, containing 1,1,1-trichloroethane. Toxicol Appl Pharmacol 38(2):369–377. 10.1016/0041-008x(76)90143-5.996867
Ellenrieder W, Reinhard M. 1988. ATHIAS-an information system for abiotic transformations of halogenated hydrocarbons in aqueous solution. Chemosphere 17(2):331–344.
El-Masri HA, Mumtaz MM, Yushak ML. 2004. Application of physiologically-based pharmacokinetic modeling to investigate the toxicological interaction between chlorpyrifos and parathion in the rat. Environ Toxicol Pharmacol 16(1–2):57–71. 10.1016/j.etap.2003.10.002.21782694
Eng LF, Ghirnikar RS, Lee YL. 2000. Glial fibrillary acidic protein: GFAP-thirty-one years (1969–2000). Neurochem Res 25(9–10):1439–1451. 10.1023/A:1007677003387.11059815
EPA. 1979. Biodegradation and treatability of specific pollutants. Cincinnati, OH: U.S. Environmental Protection Agency. EPA600979034. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=300065S9.txt. September 27, 2023.
EPA. 1981. Treatability manual volume I. Treatability data. Washington, DC: U.S. Environmental Protection Agency. EPA600282001A. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=30005R3P.txt. September 29, 2023.
EPA. 1983. Evaluation of selected halocarbons and trace gases for potential use as indicators of groundwater movement and source (and contaminant movement in the vadose zone) Washington, DC: U.S. Environmental Protection Agency. PB84117266. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB84117266.xhtml. September 27, 2023.
EPA. 1986. Methods for the determination of organic compounds in finished drinking water and raw source water. Cincinnati, OH: U.S. Environmental Protection Agency. EPA600486503. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=20016HOP.txt. November 21, 2023.
EPA. 1991. Emissions of metals and organics from municipal wastewater sludge incinerators. Cincinnati, OH: U.S. Environmental Protection Agency. EPA600S291007.
EPA. 1992. Emissions of metals, chromium and nickel species, and organics from municipal wastewater sludge incinerators. Cincinnati, OH: U.S. Environmental Protection Agency. EPA600SR92003.
EPA. 1995. Method 551.1: Determination of chlorination disinfection byproducts, chlorinated solvents, and halogenated pesticides/herbicides in drinking water by liquid-liquid extraction and gas chromatography with electron-capture detection. Revision 1.0. Cincinnati, OH: U.S. Environmental Protection Agency.
EPA. 2004. SEC. 604: Phase-out of production and consumption of Class I substances. U.S. Environmental Protection Agency.
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. EPA260B05001.
EPA. 2006a. Final report for physiologically based pharmacokinetic modeling of 1,1,1-trichloroethane (Project 04–10). U.S. Environmental Protection Agency. ORISE Subcontract 5–10329. https://ordspub.epa.gov/ords/eims/eimscomm.getfile?p_download_id=460682. September 27, 2023.
EPA. 2006b. Method 8260C: Volatile organic compounds by gas chromatography/mass spectrometry (GC/MS). U.S. Environmental Protection Agency. https://archive.epa.gov/epa/sites/production/files/2015-12/documents/8260c.pdf. November 21, 2023.
EPA. 2007. Toxicological review of 1,1,1-trichloroethane (CAS No. 71–55-6). U.S. Environmental Protection Agency. EPA635R03013.
EPA. 2009. National primary drinking water regulations. U.S. Environmental Protection Agency. EPA816F09004. https://www.epa.gov/sites/production/files/2016-06/documents/npwdr_complete_table.pdf. September 18, 2023.
EPA. 2011. Background indoor air concentrations of volatile organic compounds in North American residences (1990–2005): A compilation of statistics for assessing vapor intrusion. Washington, DC: U.S. Environmental Protection Agency. EPA520R10001.
EPA. 2012. Benchmark dose technical guidance. Washington, DC: U.S. Environmental Protection Agency. EPA100R12001. https://www.epa.gov/sites/production/files/2015-01/documents/benchmark_dose_guidance.pdf. September 27, 2023.
EPA. 2016. Six-year review 3 compliance monitoring data (2006–2011). U.S. Environmental Protection Agency. https://www.epa.gov/dwsixyearreview/six-year-review-3-compliance-monitoring-data-2006–2011. September 27, 2023.
EPA. 2018a. 2018 Edition of the drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency. EPA822F18001. https://www.epa.gov/system/files/documents/2022-01/dwtable2018.pdf. June 15, 2022.
EPA. 2018b. About acute exposure guideline levels (AEGLs). U.S. Environmental Protection Agency. https://www.epa.gov/aegl/about-acute-exposure-guideline-levels-aegls. July 26, 2018.
EPA. 2018c. Compiled AEGL values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2018-08/documents/compiled_aegls_update_27jul2018.pdf. April 12, 2020.
EPA. 2019. Method TO-15A: Determination of volatile organic compounds (VOCs) in air collected in specially prepared canisters and analyzed by gas chromatography–mass spectrometry (GC-MS). U.S. Environmental Protection Agency. https://www.epa.gov/sites/default/files/2019-12/documents/to-15a_vocs.pdf (https://www.epa.gov/sites/default/files/2019-12/documents/to-15a_vocs.pdf---). September 27, 2023.
EPA. 2021a. 2017 National emissions inventory (NEI) data: Methyl chloroform. U.S. Environmental Protection Agency. https://www.epa.gov/air-emissions-inventories/2017-national-emissions-inventory-nei-data. August 2, 2023.
EPA. 2021b. Appendix A to part 136 - Methods for organic chemical analysis of municipal and industrial wastewater. Method 601 - Purgeable halocarbons. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR Part 136. https://www.ecfr.gov/cgi-bin/text-idx?SID=cb463e03816de6583ea4a51fe0f76b55&mc=true&node=ap40.25.136_17.a&rgn=div9. March 1, 2021.
EPA. 2022a. Annual summary data: Methyl chloroform. Air quality system: Concentration by monitor. U.S. Environmental Protection Agency. https://www.epa.gov/aqs. August 17, 2023.
EPA. 2022b. Toxic chemical release inventory reporting forms and instructions: Revised 2021 version. U.S. Environmental Protection Agency. EPA740B22002. https://ordspub.epa.gov/ords/guideme_ext/guideme_ext/guideme/file/ry_2021_rfi.pdf. August 22, 2023.
EPA. 2023. East Palestine, Ohio train derailment data. U.S. Environmental Protection Agency. https://www.epa.gov/east-palestine-oh-train-derailment. August 2, 2023.
Evans EB, Balster RL. 1991. CNS depressant effects of volatile organic solvents. Neurosci Biobehav Rev 15:233–241.1852314
Evans EB, Balster RL. 1993. Inhaled 1,1,1-trichloroethane-produced physical dependence in mice: Effects of drugs and vapors on withdrawal. J Pharmacol Exp Ther 264:726–733.8437120
Falck K, Partanen P, Sorsa M, 1985. Mutascreen®, an automated bacterial mutagenicity assay. Mutat Res 150:119–125.3889612
Fan VS, Savage RE, Buckley TJ. 2007. Methods and measurements for estimating human dermal uptake of volatile organic compounds and for deriving dermal permeability coefficients. Toxicol Mech Methods 17(5):295–304. 10.1080/15376510601017801.20020953
FDA. 2022. Beverages. Subpart B - Requirements for specific standardized beverages. Bottled water. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 165.110. https://www.govinfo.gov/content/pkg/CFR-2022-title21-vol2/pdf/CFR-2022-title21-vol2-sec165-110.pdf. January 4, 2023.
FDA. 2023. Substances added to food. Washington, DC: U.S. Food and Drug Administration. https://www.cfsanappsexternal.fda.gov/scripts/fdcc/?set=FoodSubstances. September 18, 2023.
Feiler HD, Vemick AS, Starch PH. 1979. Fate of priority pollutants in POTWs. In: Eighth National Conference on: Municipal sludge management: Impact of industrial toxic materials on POTW sludge. Miami Beach, FL: Information Transfer, Inc, 72–81.
Feiler HD, Storch PJ, Southworth R. 1980. Organics in municipal sludges survey of forty cities. In: National Conference on Municipal and Industrial Sludge Composting: Materials handling. Silver Spring, MD: Information Transfer, Inc., 53–57.
Fernandez JG, Humbert BE, Droz PO, 1975. [Exposure to trichloroethylene. Assessment of absorption, excretion and metabolism in human subjects]. Arch Mal Prof 35:397–407. (French)
Fernandez JG, Droz PO, Humbert BE, 1977. Trichloroethylene exposure. Simulation of uptake, excretion, and metabolism using a mathematical model. Br J Ind Med 34(1):43–55. 10.1136/oem.34.1.43.843463
Ferrario JB, Lawler GC, DeLeon IR, 1985. Volatile organic pollutants in biota and sediments of Lake Pontchartrain. Bull Environ Contam Toxicol 34(2):246–255. 10.1007/BF01609730.3978262
Fey F, White HA, Rabin B. 1981. Development of the degranulation test system. Prog Mutat Res 1:236–244.
Finlayson-Pitts BJ, Ezell MJ, Jayaweera TM, 1992. Kinetics of the reactions of OH with methyl chloroform and methane: Implications for global tropospheric OH and the methane budget. Geophys Res Lett 19(13):1371–1374.
Fiserova-Bergerova V, Diaz ML. 1986. Determination and prediction of tissue-gas partition coefficients. Int Arch Occup Environ Health 58:75–87.3721592
Fisher J, Mahle D, Bankston L, 1997. Lactational transfer of volatile chemicals in breast milk. Am Ind Hyg Assoc J 58:425–431.9183837
Folbergrova J, Hougaard K, Westerberg E, 1984. Cerebral metabolic and circulatory effects of 1,1,1-trichloroethane, a neurotoxic industrial solvent. 2. Tissue concentrations of labile phosphates, glycolytic metabolites, citric acid cycle intermediates, amino acids, and cyclic nucleotides. Neurochem Pathol 2:55–68. 10.1007/BF02834172.6536882
Friesel P, Milde G, Steiner B. 1984. Interactions of halogenated hydrocarbons with soils. Fresenius J Anal Chem 319:160–164.
Fukabori S, Nakaaki K, Yonemoto J, 1977. On the cutaneous absorption of 1,1,1-trichloroethane. J Sci Labour 53(1):89–95.
Fuller GC, Olshan A, Puri SK, 1970. Induction of hepatic drug metabolism in rats by methylchloroform inhalation. J Pharmacol Exp Ther 175(2):311–317.4394799
Gallagher JS, Kurt TL. 1990. Neonatal exposure to methyl chloroform in tape remover. Vet Hum Toxicol 32(1):43–45.2301149
Galloway SM, Armstrong MJ, Reuben C, 1987. Chromosome aberrations and sister chromatid exchanges in Chinese hamster ovary cells: Evaluations of 108 chemicals. Environ Mol Mutagen 10:1–175.3319609
Gamberale F, Hultengren M. 1973. Methylchloroform exposure. II. Psychophysiological functions. Scand J Work Environ Health 10:82–92.
Garabrant DH, Lacey JV, Laing TJ, 2003. Scleroderma and solvent exposure among women. Am J Epidemiol 157(6):493–500.12631538
Garcia JP, Beyne-Masclet S, Mouvier G, 1992. Emissions of volatile organic compounds from coal-fired power stations. Atmos Environ 26A(9):1589–1597.
Gargas ML, Andersen ME. 1989. Determining kinetic constants of chlorinated ethane metabolism in the rat from rates of exhalation. Toxicol Appl Pharmacol 99:344–353.2734795
Gargas ML, Andersen ME, Clewell HJ. 1986. A physiologically based simulation approach for determining metabolic constants from gas uptake data. Toxicol Appl Pharmacol 86:341–352.3787629
Gargas ML, Burgess RJ, Voisard DE, 1989. Partition coefficients of low-molecular-weight volatile chemicals in various liquids and tissues. Toxicol Appl Pharmacol 98:87–99.2929023
Garnier R, Reygagne A, Maladry-Muller P, 1991. [Evolution of chronic toxic encephalopathy induced by organic solvents after the cessation of exposure - report of a case with a 5-year followup]. Arch Mal Prof 52:349–354. (French)
Gatehouse D. 1981. Mutagenic activity of 42 coded compounds in the "microtiter" fluctuation test. Prog Mutat Res 1:376–386.
Gehring PJ. 1968. Hepatotoxic potency of various chlorinated hydrocarbon vapours relative to their narcotic and lethal potencies in mice. Toxicol Appl Pharmacol 13:287–298.5726658
Geller I, Mendez V, Hartmann RJ, 1982. Effects of 1,1,1-trichloroethane on a match-to-sample discrimination task in the baboon. J Toxicol Environ Health 9:783–795. 10.1080/15287398209530203.7120510
George JD, Price CJ, Marr MC, 1989. Developmental toxicity of 1,1,1-trichloroethane in CD rats. Fundam Appl Toxicol 13:641–651. 10.1016/0272-0590(89)90322-9.2620788
Ghittori S, Imbriani M, Pezzagno G, 1987. The urinary concentration of solvents as a biological indicator of exposure: Proposal for the biological equivalent exposure limit for nine solvents. Am Ind Hyg Assoc J 48(9):786–790.3687738
Giardino NJ, Gordon SM, Brinkman MC, 1999. Real-time breath analysis of vapor phase uptake of 1,1,1 trichloroethane through the forearm: implications for daily absorbed dose of volatile organic compounds at work. Appl Occup Environ Hyg 14(11):719–727. 10.1080/104732299302116.10590543
Gill R, Hatchett SE, Broster CG, 1991. The response of evidential breath alcohol testing instruments with subjects exposed to organic solvents and gases. I. Toluene, 1,1,1-trichloroethane and butane. Med Sci Law 31(3):187–200. 10.1177/002580249103100302.1822580
Gocke E, King MT, Eckhardt K, 1981. Mutagenicity of cosmetics ingredients licensed by the European communities. Mutat Res 90:91–109.6799819
Gold LS, Stewart PA, Milliken K, 2011. The relationship between multiple myeloma and occupational exposure to six chlorinated solvents. Occup Environ Med 68(6):391–399. 10.1136/oem.2009.054809.20833760
Gong X, Lin Y, Zhan FB. 2018. Industrial air pollution and low birth weight: a case-control study in Texas, USA. Environ Sci Pollut Res 25(30):30375–30389. 10.1007/s11356-018-2941-y.
Gossett JM. 1987. Measurement of Henry's Law constant for C1 and C2 chlorinated hydrocarbons. Environ Sci Technol 21(2):202–206.
Graber ER, Sorek A, Tsechansky L, 2007. Competitive uptake of trichloroethene and 1,1,1-trichloroethane by Eucalyptus camaldulensis seedlings and wood. Environ Sci Technol 41(19):6704–6710. 10.1021/es070743l.17969684
Gradiski D, Bonnet P, Raoult G, 1978. [Compared acute pulmonary toxicity of the main chlorinated aliphatic solvents]. Arch Mal Prof 39(4–5):249–257. (French)
Green MH L. 1981. A differential killing test using an improved repair-deficient strain of Escherichia coli. Prog Mutat Res 1:183–194.
Green AE S, Wagner JC M, S. 1992. Chlorinated toxics from incineration. In: Gupta AK, Presser G, Axelbaum RL, eds. Air toxic reduction and combustion modeling: Presented at the 1992 International Joint Power Generation Conference. FACT-Volume 15. Atlanta, GA: American Society of Mechanical Engineers, 49–56.
Gresham GA, Treip CS. 1983. Fatal poisoning by 1,1,1-trichloroethane after prolonged survival. Forensic Sci Int 23:249–253.6662442
Guberan E, Fryc O, Robert M. 1976. [Sudden death by ventricular fibrillation, after voluntary inhalation of chlorothene, in an apprentice mechanic]. Schweiz Med Wochenschr 106(4):119–121. (French)1251163
Guengerich FP, Kim D, Iwasaki M. 1991. Role of human cytochrome P-450 IIE1 in the oxidation of many low molecular weight cancer suspects. Chem Res Toxicol 4(2):168–179. 10.1021/tx00020a008.1664256
Guo P, Yokoyama K, Piao F, 2013. Sick building syndrome by indoor air pollution in Dalian, China. Int J Environ Res Public Health 10(4):1489–1504. 10.3390/ijerph10041489.23579877
Haag WR, Mill T. 1988. Effect of a subsurface sediment on hydrolysis of haloalkanes and epoxides. Environ Sci Technol 22:658–663.
Haddad S, Pelekis M, Krishnan K. 1996. A methodology for solving physiologically based pharmacokinetic models without the use of simulation softwares. Toxicol Lett 85(2):113–126. 10.1016/0378-4274(96)03648-x.8650694
Haddad S, Tardif GC, Tardif R. 2006. Development of physiologically based toxicokinetic models for improving the human indoor exposure assessment to water contaminants: trichloroethylene and trihalomethanes. J Toxicol Environ Health A 69(23):2095–2136. 10.1080/15287390600631789.17060096
Hajimiragha H, Ewers U, Jansen-Rosseck R, 1986. Human exposure to volatile halogenated hydrocarbons from the general environment. Int Arch Occup Environ Health 58:141–150.3744568
Hake CL, Waggoner TB, Robertson DN, 1960. The metabolism of 1,1,1-trichloroethane by the rat. Arch Environ Health 1:101–105. 10.1080/00039896.1960.10662673.14398915
Halevy J, Pitlik S, Rosenfeld J, 1980. 1,1,1-Trichloroethane intoxication: A case report with transient liver and renal damage. Review of the literature. Clin Toxicol 16(4):467–472.7408423
Hall DW. 1984. Volatile organic contamination in an alluvial aquifer, Southington, Connecticut. In: International Conference: Hazardous Wastes Environmental Emergency Management, Prevention, Cleanup, Control. 190–197.
Hall FB, Hine CH. 1966. Trichloroethane intoxication: A report of two cases. J Forensic Sci 11(3):404–413.4973525
Hallen RT, Pyne JR, Molton PM. 1986. Transformation of chlorinated ethenes and ethanes by anaerobic microorganisms. In: 192nd National Meeting: ACS Division of Environmental Chemistry. Vol. 26. Anaheim, CA: Pacific Northwest Laboratories, 344–346.
Hamada T, Tanaka H. 1995. Transfer of methyl chloroform, trichloroethylene and tetrachloroethylene to milk, tissues and expired air following intraruminal or oral administration in lactating goats and milk-fed kids. Environ Pollut 87(3):313–318. 10.1016/0269-7491(94)p4163-i.15091581
Hanasono GK, Witschi H, Plaa GL. 1975. Potentiation of the hepatotoxic responses to chemicals in alloxan-diabetic rats. Proc Soc Exp Biol Med 149:903–907.1166087
Hansch C, Leo AJ. 1985. Medchem project issue no.26. Claremont, CA: Pomona College.
Harkov R, Gianti SJ, Bozzelli JW, 1985. Monitoring volatile organic compounds at hazardous and sanitary landfills in New Jersey. J Environ Sci Health 20(5):491–501.
Hartwell TD, Pellizzari ED, Perritt RL, 1987. Comparison of volatile organic levels between sites and seasons for the total exposure assessment methodology (TEAM) study. Atmos Environ 21(11):2413–2424. 10.1016/0004-6981(87)90376-3.
Hatch GG, Mamay PD, Ayer ML, 1982. Methods for detecting gaseous and volatile carcinogens using cell transformation assays. Environ Sci Res 25:75–90.
Hatch GG, Mamay PD, Ayer ML, 1983. Chemical enhancement of viral transformation in Syrian hamster embryo cells by gaseous and volatile chlorinated methanes and ethanes. Cancer Res 43(5):1945–1950.6299533
Haynes W, Lide D, Bruno T. 2015. 1,1,1-Trichloroethane. In: Haynes W, Lide D, Bruno T, eds. CRC handbook of chemistry and physics: A ready-reference book of chemical and physical data. 95^th^ ed. Boca Raton, FL: CRC Press, 3–520.
Heikes DL, Jensen SR, Fleming-Jones ME. 1995. Purge and trap extraction with GC-MS determination of volatile organic compounds in table-ready foods. J Agric Food Chem 43:2869–2875.
Hein MJ, Waters MA, Ruder AM, 2010. Statistical modeling of occupational chlorinated solvent exposures for case-control studies using a literature-based database. Ann Occup Hyg 54(4):459–472. 10.1093/annhyg/meq027.20418277
Heineman EF, Cocco P, Gomez MR, 1994. Occupational exposure to chlorinated aliphatic hydrocarbons and risk of astrocytic brain cancer. Am J Ind Med 26:155–169. 10.1002/ajim.4700260203.7977393
Henson JM, Yates MV, Cochran JW, 1988. Microbial removal of halogenated methanes, ethanes, and ethylenes in an aerobic soil exposed to methane. FEMS Microbiol Ecol 53:193–201.
Herd PA, Lipsky M, Martin HF. 1974. Cardiovascular effects of 1,1,1-trichloroethane. Arch Environ Health 28:227–233. 10.1080/00039896.1974.10666473.4814959
Hobara T, Kobayashi H, Iwamoto S, 1981. [Diminution of 1,1,1- and 1,1,2-trichloroethane in the blood and their excretion by the lungs]. Sangyo Igaku 23:377–382. 10.1539/joh1959.23.377. (Japanese)7321282
Hobara T, Kobayashi H, Higashihara E, 1982. [Experimental examinations and toxicokinetic analysis of the absorption and excretion of 1,1,1-trichloroethane by the lung]. Sangyo Igaku 24(6):599–607. 10.1539/joh1959.24.599. (Japanese)7182601
Hobara T, Kobayashi H, Higashihara E, 1983a. [The effects of several factors on 1,1,1-trichloroethane absorption and excretion by the lungs]. Nippon Eiseigaku Zasshi 38:642–648. (Japanese)6655980
Hobara T, Kobayashi H, Higashihara E, 1983b. Changes in hematologic parameters with acute exposure to 1,1,1-trichloroethane. Ind Health 21:255–261.6654708
Hodgson MJ, Heyl AE, Van Thiel DH. 1989. Liver disease associated with exposure to 1,1,1-trichloroethane. Arch Intern Med 149(8):1793–1798.2669664
Holmberg B, Jakobson I, Sigvardsson K. 1977. A study on the distribution of methylchloroform and n-octane in the mouse during and after inhalation. Scand J Work Environ Health 3:43–52.847431
Horiguchi S, Horiuchi K. 1971. [An experiment of 1,1,1-trichloroethane vapor exposure to mice: Supplementary report on the toxicity of 1,1,1-trichloroethane I]. Sangyo Igaku 13(3):226–227. 10.1539/joh1959.13.226. (Japanese)
Hougaard K, Ingvar M, Wieloch T, 1984. Cerebral metabolic and circulatory effects of 1,1,1-trichloroethane, a neurotoxic industrial solvent. 1. Effects on local cerebral glucose consumption and blood flow during acute exposure. Neurochem Pathol 2:39–53. 10.1007/BF02834171.6536881
House RA, Liss GM, Wills MC. 1994. Peripheral sensory neuropathy associated with 1,1,1-trichloroethane. Arch Environ Health 49(3):196–199.8185391
House RA, Liss GM, Wills MC, 1996. Paresthesias and sensory neuropathy due to 1,1,1-trichloroethane. J Occup Environ Med 38(2):123–124.
Howse DC, Shanks GL, Nag S. 1989. Peripheral neuropathy following prolonged exposure to methyl chloroform [abstract]. Neurology 39(Suppl 1):242.
Hubbard SA, Green MH L, Bridges BA, 1981. Fluctuation test with S9 and hepatocyte activation. Prog Mutat Res 1:361–370.
Hubrich C, Stuhl F. 1980. The ultraviolet adsoprtion of some halogenated methanes and ethanes of atmospheric interest. J Photochem 12:93–107.
Hughes JB, Parkin GF. 1992. The effect of mixtures of xenobiotics and primary electron donor on the anaerobic biotransformations of high concentrations of chlorinated aliphatics. Water Sci Technol 26(1–2):117–126.
Humbert BE, Fernandez JG. 1977. [1,1,1-Trichloroethane exposure. Study of absorption, excretion and metabolism by human subjects]. Arch Mal Prof 38:415–425. (French)
IARC. 2022. 1,1,1-Trichloroethane and four other industrial chemicals. Volume 110: IARC Monographs on the identification of carcinogenic hazards to humans. Lyon, France: International Agency for Research on Cancer. https://publications.iarc.fr/_publications/media/download/6997/adc10f3c027ff5170f3c4b675b4f8603d2889a20.pdf. September 28, 2023.
Ichinotsubo D, Mower H, Mandel M. 1981. Testing of a series of paired compounds (carcinogen and noncarcinogenic structural analog) by DNA repair-deficient E. coli strains. Prog Mutat Res 1:195–198.
Ikatsu H, Nakajima T. 1992. Hepatotoxic interaction between carbon tetrachloride and chloroform in ethanol treated rats. Arch Toxicol 66(8):580–586. 10.1007/BF01973389.1463393
Ikeda M, Ohtsuji H. 1972. A comparative study of the excretion of Fujiwara reaction-positive substances in urine of humans and rodents given trichloro- or tetrachloro- derivatives of ethane and ethylene. Br J Ind Med 29(1):99–104. 10.1136/oem.29.1.99.5060252
Imbriani M, Ghittori S, Pezzagno G, 1988. 1,1,1-Trichloroethane (methyl chloroform) in urine as biological index of exposure. Am J Ind Med 13:211–222.3354575
Infante-Rivard C, Siemiatycki J, Lakhani R, 2005. Maternal exposure to occupational solvents and childhood leukemia. Environ Health Perspect 113(6):787–792. 10.1289/ehp.7707.15929905
Ingber A. 1991. Occupational allergic contact dermatitis from methyl chloroform (1,1,1-trichloroethane). Contact Dermatitis 25(3):193. 10.1111/j.1600-0536.1991.tb01831.x.
IRIS. 2007. Integrated risk information system (IRIS). Chemical assessment summary. 1,1,1-trichloroethane; CASRN 71–55-6. U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0197_summary.pdf. September 18, 2023.
Isacson P, Bean JA, Splinter R, 1985. Drinking water and cancer incidence in Iowa. III. Association of cancer with indices of contamination. Am J Epidemiol 121(6):856–869.4014178
Ivanetich KM, Van den Honert LH. 1981. Chloroethanes: Their metabolism by hepatic cytochrome P-450 in vitro. Carcinogenesis 2(8):697–702.7285278
Iyadomi M, Ichiba M, Zhang J, 2000. Evaluation of skin irritants caused by organic solvents by means of the mouse ear thickness measurement method. J Occup Health 42:44–46.
Jagannath DR, Vultaggio DM, Brusick DJ. 1981. Genetic activity of 42 coded compounds in the mitotic gene conversion assay using Saccharomyces cerevisiae strain D4. Prog Mutat Res 1:456–467.
Jiang Z, Taylor PH, Dellinger B. 1992. Laser photolysis/laser-induced fluorescence studies of the reaction of hydroxyl with 1,1,1-trichloroethane over an extended temperature range. J Phys Chem 96(22):8961–8964.
Johns DO, Daniell WE, Shen DD, 2006. Ethanol-induced increase in the metabolic clearance of 1,1,1-trichloroethane in human volunteers. Toxicol Sci 92(1):61–70. 10.1093/toxsci/kfj210.16638923
Jones RD, Winter DP. 1983. Two case reports of deaths on industrial premises attributed to 1,1,1-trichloroethane. Arch Environ Health 38(1):59–61.6830317
Jones HE, Kunko PM, Robinson SE, 1996. Developmental consequences of intermittent and continuous prenatal exposure to 1,1,1-trichloroethane in mice. Pharmacol Biochem Behav 55(4):635–646. 10.1016/s0091-3057(96)00288-2.8981595
Jung WT, Fujita M, Sohn DH. 1992. Levels of volatile halogenated hydrocarbons in Tokyo rain and their seasonal time-series changes. Jpn J Environ Toxicol Health 38(6):490–497. 10.1248/jhs1956.38.490.
Kada T. 1981. The DNA-damaging activity of 42 coded compounds in the rec-assay. Prog Mutat Res 1:175–182.
Kaiser KL E, Comba ME. 1986. Tracking river plumes with volatile halocarbon contaminants: The St. Clair River-Lake St. Clair example. Environ Toxicol Chem 5:965–976.
Kaiser KL E, Comba ME, Huneault H. 1983. Volatile halocarbon contaminants in the Niagara River and in Lake Ontario. J Great Lakes Res 9(2):212–223.
Kaneko T, Wang PY, Sato A. 1994. Enzymes induced by ethanol differently affect the pharmacokinetics of trichloroethylene and 1,1,1-trichloroethane. Occup Environ Med 51(2):113–119. 10.1136/oem.51.2.113.8111458
Kapp RW. 2014. Trichloroethane. In: Wexler P, ed. Encyclopedia of toxicology. 3rd ed. Oxford: Academic Press, 823–826. 10.1016/B978-0-12-386454-3.00955-6.
Kassinova GV, Kovaltsova SV, Marfin SV, 1981. Activity of 40 coded compounds in differential inhibition and mitotic crossing-over assays in yeast. Prog Mutat Res 1:434–455.
Katagiri H, Aoki N, Soma K, 1997. Concentration in blood and organs of dogs after high dose 1,1,1-trichloroethane inhalation. Ind Health 35:461–466.9348717
Kataz M, Heddle JA, Salamone MF. 1981. Mutagenic activity of polycyclic aromatic hydrocarbons and other environmental pollutants. In: Cooke M, Dennis AJ, eds. Polynuclear aromatic hydrocarbons: Chemical analysis and biological fate. Columbus, OH: Battelle Press, 519–528.
Kawai T, Yamaoka K, Uchida Y, 1991. Exposure of 1,1,1-trichloroethane and dose-related excretion of metabolites in urine of printing workers. Toxicol Lett 55:39–45.1998196
Kawamura K, Kaplan IR. 1983. Organic compounds in the rainwater of Los Angeles. Environ Sci Technol 17(8):497–501. 10.1021/es00114a011.22283170
Kefalas V, Stacey NH. 1991. Potentiating effects of chlorinated hydrocarbons on carbon tetrachloride toxicity in isolated rat hepatocytes and plasma membranes. Toxicol Appl Pharmacol 109:171–179.1828122
Kelafant GA, Berg RA, Schleenbaker R. 1994. Toxic encephalopathy due to 1,1,1-trichloroethane exposure. Am J Ind Med 25:439–446.8160661
Kelly KJ, Ruffing R. 1993. Acute eosinophilic pneumonia following intentional inhalation of Scotchguard. Ann Allergy 71(4):358–361.8214799
Kernan GJ, Ji B, Dosemeci M, 1999. Occupational risk factors for pancreatic cancer: A case-control study based on death certificates from 24 U.S. states. Am J Ind Med 36:260–270.10398934
Kezic S, Monster AC, Kruse J, 2000. Skin absorption of some vaporous solvents in volunteers. Int Arch Occup Environ Health 73:415–422.11007346
Kezic S, Monster AC, van de Gevel IA, 2001. Dermal absorption of neat liquid solvents on brief exposures in volunteers. Am Ind Hyg Assoc J 62:12–18.
Kim J, Bhagwandin S, Labow DM. 2017. Malignant peritoneal mesothelioma: a review. Ann Transl Med 5(11):236. 10.21037/atm.2017.03.96.28706904
Kincannon DF, Stover EL, Nicholes V, 1983a. Removal mechanisms for toxic priority pollutants. J Water Pollut Control Fed 55(2):157–163.
Kincannon DF, Weinert A, Padorr R, 1983b. Predicting treatability of multiple organic priority pollutant waste water from single-pollutant treatability studies. In: John MB, ed. Proceedings of the 37th Industrial Waste Conference, May 11, 12, and 13, 1982. Ann Arbor, MI: Ann Arbor Science Publishers, 641–650.
Kinkead ER, Wolfe RE. 1992. Single oral toxicity of various organic compounds. J Am Coll Toxicol 11(6):713.
Kjellstrand P, Bjerkemo M, Adler-Maihofer M, 1985a. Effects of solvent exposure on testosterone levels and butyrylcholinesterase activity in mice. Acta Pharmacol Toxicol 57:242–249. 10.1111/j.1600-0773.1985.tb00038.x.
Kjellstrand P, Holmquist B, Jonsson I, 1985b. Effects of organic solvents on motor activity in mice. Toxicology 35:35–46.4002237
Klaassen CD, Plaa GL. 1966. Relative effects of various chlorinated hydrocarbons on liver and kidney function in mice. Toxicol Appl Pharmacol 9:139–151.5967557
Klaassen CD, Plaa GL. 1967. Relative effects of various chlorinated hydrocarbons on liver and kidney function in dogs. Toxicol Appl Pharmacol 10:119–131.6031921
Klaassen C, Amdur M, Doull J. 1996. Toxic effects of solvents and vapors. In: Casarett and Doull’s toxicology: The basic science of poisons. 5th ed. New York, NY: McGraw Hill, online.
Klecka GM, Gonsior SJ. 1984. Reductive dechlorination of chlorinated methanes and ethanes by reduced iron (II) porphyrins. Chemosphere 13(3):391–402.
Klecka GM, Gonsior SJ, Markham DA. 1990. Biological transformations of 1,1,1-trichloroethane in subsurface soils and ground water. Environ Toxicol Chem 9:1437–1451.
Klingler M, Demmelmair H, Larque E, 2003. Analysis of FA contents in individual lipid fractions from human placental tissue. Lipids 38(5):561–566.12880113
Koizumi A, Kumai M, Ikeda M. 1982. In vivo suppression of 1,1,1-trichloroethane metabolism by co-administered tetrachloroethylene: an inhalation study. Bull Environ Contam Toxicol 29(2):196–199. 10.1007/bf01606150.7126908
Koizumi A, Kumai M, Ikeda M. 1983. Dose-dependent induction and suppression of liver mixed-function oxidase system in chlorinated hydrocarbon solvent metabolism. J Appl Toxicol 3(4):208–217. 10.1002/jat.2550030409.6643917
Kramer CG, Ott MG, Fulkerson JE, 1978. Health of workers exposed to 1,1,1-trichloroethane: A matched-pair study. Arch Environ Health 33:331–342. 10.1080/00039896.1978.10667357.736618
Krantz JC, Park CS, Ling JS L. 1959. Anesthesia LX: The anesthetic properties of 1,1,1-trichloroethane. Anesthesiology 20(5):635–640. 10.1097/00000542-195909000-00015.14411702
Krishnan K, Andersen ME, Clewell HJ, 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RS H, ed. Toxicology of chemical mixtures: Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Kronevi T, Wahlberg JE, Holmberg B. 1981. Skin pathology following epicutaneous exposure to seven organic solvents. Int J Tissue React 3(1):21–30.7026421
Kumagai S. 2014. Two offset printing workers with cholangiocarcinoma. J Occup Health 56(2):164–168. 10.1539/joh.13-0262-cs.24553624
Kusakabe K, Aso S, Wada T, 1991. Destruction rate of volatile organochlorine compounds in water by ozonation with ultraviolet radiation. Water Res 25(10):1199–1203.
Kyrklund T, Haglid KG. 1991. Exposure of rats to high concentrations of 1,1,1-trichloroethane and its effects on brain lipid and fatty acid composition. Pharmacol Toxicol 68:384–386.1946184
Kyrklund T, Kjellstrand P, Haglid KG. 1988. Effects of exposure to Freon 11, 1,1,1-trichloroethane or perchloroethylene on the lipid and fatty-acid composition of rat cerebral cortex. Scand J Work Environ Health 14:91–94.3387963
Laine A, Seppalainen AM, Savolainen K, 1996. Acute effects of 1,1,1-trichloroethane inhalation on the human central nervous system. Int Arch Occup Environ Health 69:53–61. 10.1007/BF02630739.9017435
Lal H, Shah HC. 1970. Effect of methylchloroform inhalation on barbiturate hypnosis and hepatic drug metabolism in male mice. Toxicol Appl Pharmacol 17:625–633.5528147
Lancar I, Le Bras G, Poulet G. 1993. Oxidation of CH3CCL3 and CH3CFCl2 in the atmosphere: kinetic study of OH reactions. J Chem Phys 90:1897–1908.
Lane RW, Riddle BL, Borzelleca JF. 1982. Effects of 1,2-dichloroethane and 1,1,1-trichloroethane in drinking water on reproduction and development in mice. Toxicol Appl Pharmacol 63:409–421. 10.1016/0041-008X(82)90270-8.7201685
Laparé S, Tardif R, Brodeur J. 1995. Effect of various exposure scenarios on the biological monitoring of organic solvents in alveolar air. II. 1,1,1-Trichloroethane and trichloroethylene. Int Arch Occup Environ Health 67:375–394.8567088
Lazarew NW. 1929. [Concerning the strength of the narcotic effects of the vapors of the chlorine derivatives of the methanes, ethanes and ethylenes]. Naunyn-Schmiedebergs Arch Exp Pathol Pharmakol 141:19–24. (German)
Legault R, Blaise C, Rokosh D, 1994. Comparative assessment of the SOS Chromotest kit and the Mutatox test with the Salmonella plate incorporation (Ames test) and fluctuation tests for screening genotoxic agents. Environ Toxicol Water Qual 9(1):45–57. 10.1002/tox.2530090107.
Leisinger T. 1992. Microorganisms for the introduction of chlorinated aliphatic hydrocarbons into the carbon cycle. In: Mongkolsuk S, Lovett PS, Trempy JE, eds. Biotechnology and environmental science: Molecular approaches: International Conference, Bangkok, Thailand, August 21–24, 1990. New York: Plenum Press, 143–147.
Leung H. 1992. Use of physiologically based pharmacokinetic models to establish biological exposure indexes. Am Ind Hyg Assoc J 53(6):369–374.1605109
Li X, Guo Y, Song X, 2019. A cross-sectional survey based on blood VOCs, hematological parameters and urine indicators in a population in Jilin, Northeast China. Environ Geochem Health 41(3):1599–1615. 10.1007/s10653-019-00241-6.30648198
Lindahl-Kiessling K, Karlberg I, Olofsson AM. 1989. Induction of sister-chromatid exchanges by direct and indirect mutagens in human lymphocytes, co-cultured with intact rat liver cells: Effect of enzyme induction and preservation of the liver cells by freezing in liquid nitrogen. Mutat Res 211:77–87.2922003
Lindbohm ML, Taskinen H, Sallmen M, 1990. Spontaneous abortions among women exposed to organic solvents. Am J Ind Med 17:449–463. 10.1002/ajim.4700170404.2327413
Liss GM. 1988. Peripheral neuropathy in two workers exposed to 1,1,1-trichloroethane. JAMA 260(15):2217.2845159
Liu B, Jia C. 2015. Effects of exposure to mixed volatile organic compounds on the neurobehavioral test performance in a cross-sectional study of US adults. Int J Environ Health Res 25(4):349–363. 10.1080/09603123.2014.945514.25130197
Loprieno N. 1981. Screening of coded carcinogenic/noncarcinogenic chemicals by a forward-mutation system with the yeast Schizosaccharomyces pombe. Prog Mutat Res 1:424–433.
Lu Y, Rieth S, Lohitnavy M, 2008. Application of PBPK modeling in support of the derivation of toxicity reference values for 1,1,1-trichloroethane. Regul Toxicol Pharmacol 50(2):249–260. 10.1016/j.yrtph.2007.12.001.18226845
Lue-Hing C, Lordi DT, Kelada NP. 1980. Fate of priority pollutants in large municipal treatment plants. AIChE Symp Ser 77(209):144–150.
Lyman WJ, Reehl WF, Rosenblatt DH. 1990. 1,1,1-Trichloroethane. In: Handbook of chemical property estimation methods. Washington, DC: American Chemical Society, 4–1 to 4–33.
MacDonald DJ. 1981. Salmonella/microsome tests on 42 coded chemicals. Prog Mutat Res 1:285–297.
MacDougall IC, Isles C, Oliver JS, 1987. Fatal outcome following inhalation of Tipp-Ex. Scottish Med J 32:55.
MacEwen JD, Vernot EH. 1974. The biological effect of continuous inhalation exposure of 1,1,1-trichloroethane (methyl chloroform) on animals. AMRLTR7478. In: Toxic Hazards Research Unit annual report: 1974. Wright Patterson Air Force Base, OH: Aerospace Medical Research Laboratory Report, 81–90.
Mackay CJ, Campbell L, Samuel AM, 1987. Behavioral changes during exposure to 1,1,1-trichloroethane: Time-course and relationship to blood solvent levels. Am J Ind Med 11(223–240) 10.1002/ajim.4700110210.
Maltoni C, Cotti G, Patella V. 1986. Results of long-term carcinogenicity bioassays on Sprague-Dawley rats of methyl chloroform, administered by ingestion. Acta Oncol 7(2):101–117.
Maroni M, Bulgheroni C, Cassitto MG, 1977. A clinical, neurophysiological and behavioral study of female workers exposed to 1,1,1-trichloroethane. Scand J Work Environ Health 3:16–22. 10.5271/sjweh.2797.139679
Mart CJ, Henke CB. 1992. Emissions from the incineration of nerve agent rockets containing low-level PCBs. J Environ Sci Health A 27(6):1549–1575.
Martin CN, McDermid AC. 1981. Testing of 42 coded compounds for their ability to induce unscheduled DNA repair synthesis in HeLa cells. Prog Mutat Res 1:533–537.
Marzulli FN, Ruggles DI. 1973. Rabbit eye irritation test: Collaborative study. J Assoc Off Anal Chem 56(4):905–914. 10.1093/jaoac/56.4.905.
Matsushima T, Takamoto Y, Shirai A, 1981. Reverse mutation test on 42 coded compounds with the E. coli WP2 system. Prog Mutat Res 1:387–395.
Mattie DR, Bates GD, Jepson GW, 1994. Determination of skin:air partition coefficients for volatile chemicals: experimental method and applications. Fundam Appl Toxicol 22:51–57.8125213
Mattsson JL, Albee RR, Lomax LG, 1993. Neurotoxicologic examination of rats exposed to 1,1,1-trichloroethane vapor for 13 weeks. Neurotoxicol Teratol 15:313–326. 10.1016/0892-0362(93)90033-k.8277925
Maurissen JP J, Shankar MR, Zielke GJ, 1994. Lack of developmental cognitive and other neurobehavioral effects following maternal exposure to 1,1,1-trichloroethane in rates. Toxicologist 14(1):163.
McCarthy TB, Jones RD. 1983. Industrial gassing poisonings due to trichlorethylene, perchlorethylene, and 1–1-1 trichloroethane, 1961–80. Br J Ind Med 40(4):450–455. 10.1136/oem.40.4.450.6626474
McCarty PL. 1993. In situ bioremediation of chlorinated solvents. Curr Opin Biotechnol 4:323–330.
McCarty PL, Reinhard M. 1980. Trace organics removal by advanced wastewater treatment. J Water Pollut Control Fed 52:1907–1922.
McLean D, Fleming S, Turner MC, 2014. Occupational solvent exposure and risk of meningioma: results from the INTEROCC multicentre case-control study. Occup Environ Med 71(4):253–258. 10.1136/oemed-2013-101780.24474387
McNutt NS, Amster RL, McConnell EE, 1975. Hepatic lesions in mice after continuous inhalation exposure to 1,1,1-trichloroethane. Lab Invest 32(5):642–654.1127881
Mehta RD, von Borstel RC. 1981. Mutagenic activity of 42 encoded compounds in the haploid yeast reversion assay, strain XV185–14C. Prog Mutat Res 1:414–423.
Meredith TJ, Ruprah M, Liddle A, 1989. Diagnosis and treatment of acute poisoning with volatile substances. Hum Toxicol 8(4):277–286. 10.1177/096032718900800405.2777267
Mertens J A,. 2000. Trichloroethylene. In: Kirk-Othmer encyclopedia of chemical technology. New York, NY: John Wiley & Sons, Inc., online. 10.1002/0471238961.2018090313051820.a01.
Miller LJ, Uhler AD. 1988. Volatile halocarbons in butter: Elevated tetrachloroethylene levels in samples obtained in close proximity to dry-cleaning establishments. Bull Environ Contam Toxicol 41(3):469–474. 10.1007/BF01688895.3219441
Millet DB, Goldstein AH. 2004. Evidence of continuing methylchloroform emissions from the United States. Geophys Res Lett 31(17):L17101. 10.1029/2004GL020166.
Milman HA, Story DL, Riccio ES, 1988. Rat liver foci and in vitro assays to detect initiating and promoting effects of chlorinated ethanes and ethylenes. Ann N Y Acad Sci 534:521–530. 10.1111/j.1749-6632.1988.tb30143.x.3389679
Mitchell AD, Rudd CJ, Caspary WJ. 1988. Evaluation of the L5178Y mouse lymphoma cell mutagenesis assay: Intralaboratory results for sixty-three coded chemicals tested at SRI International. Environ Mol Mutagen 12:37–101.3416841
Mitoma C, Steeger T, Jackson SE, 1985. Metabolic disposition study of chlorinated hydrocarbons in rats and mice. Drug Chem Toxicol 8(3):183–194. 10.3109/01480548508999169.4054011
Mizunuma K, Kawai T, Horiguchi S, 1995. Urinary methylchloroform rather than urinary metabolites as an indicator of occupational exposure to methylchloroform. Int Arch Occup Environ Health 67:19–25.7622275
Monster AC. 1986. Biological monitoring of chlorinated hydrocarbon solvents. J Occup Med 28(8):583–588.3746478
Monster AC. 1988. Biological markers of solvent exposure. Arch Environ Health 43(2):90–93.3377562
Monster AC, Houtkooper JM. 1979. Estimation of individual uptake of trichloroethylene, 1,1,1-trichloroethane and tetrachloroethylene from biological parameters. Int Arch Occup Environ Health 42(3–4):319–323. 10.1007/bf00377786.422273
Monster AC, Boersma G, Steenweg H. 1979. Kinetics of 1,1,1-trichloroethane in volunteers; influence of exposure concentration and work load. Int Arch Occup Environ Health 42:293–301.422270
Morgan A, Black A, Belcher DR. 1970. The excretion in breath of some aliphatic halogenated hydrocarbons following administration by inhalation. Ann Occup Hyg 13:219–233.5509094
Morgan A, Black A, Belcher DR. 1972a. Studies on the absorption of halogenated hydrocarbons and their excretion in breath using 38Cl tracer techniques. Ann Occup Hyg 15:273–282.4648240
Morgan A, Black A, Walsh M, 1972b. The absorption and retention of inhaled fluorinated hydrocarbon vapours. Int J Appl Radiat Isot 23(6):285–291. 10.1016/0020-708x(72)90076-2.5043361
Morgan DL, Cooper SW, Carlock DL, 1991. Dermal absorption of neat and aqueous volatile organic chemicals in the Fischer 344 rat. Environ Res 55(1):51–63. 10.1016/s0013-9351(05)80140-9.1855490
Mortuza T, Muralidhara S, White CA, 2018. Effect of dose and exposure protocol on the toxicokinetics and first-pass elimination of trichloroethylene and 1,1,1-trichloroethane. Toxicol Appl Pharmacol 360:185–192. 10.1016/j.taap.2018.09.043.30287391
Moser VC, Balster RL. 1985. Acute motor and lethal effects of inhaled toluene, 1,1,1-trichloroethane, halothane, and ethanol in mice: Effects of exposure duration. Toxicol Appl Pharmacol 77:285–291.3975901
Moser VC, Balster RL. 1986. The effects of inhaled toluene, halothane, 1,1,1-trichloroethane, and ethanol on fixed-interval responding in mice. Neurobehav Toxicol Teratol 8(5):525–532.3785514
Moser VC, Scimeca JA, Balster RL. 1985. Minimal tolerance to the effects of 1,1,1-trichloroethane on fixed-ratio responding in mice. Neurotoxicology 6(1):35–42.
Mudder TI, Musterman JL. 1982. Development of empirical structure biodegradability relationships and biodegradability testing protocol for volatile and slightly soluble priority pollutants. In: Division of Environmental Chemistry of the American Chemical Society. Kansas City, MO: 52–53.
Mulla ZD. 1996. Toxic chemicals and childhood brain tumors. FAPTP Footnotes. Tampa, FL: Florida Association of Pediatric Tumor Programs Inc. 1–3.
Mullin LS, Krivanek ND. 1982. Comparison of unconditioned reflex and conditioned avoidance tests in rats exposed by inhalation to carbon monoxide, 1,1,1-trichloroethane, toluene or ethanol. Neurotoxicology 3(1):126–137.6890184
Mumtaz MM, Ray M, Crowell SR, 2012a. Translational research to develop a human PBPK models tool kit-volatile organic compounds (VOCs). J Toxicol Environ Health A 75(1):6–24. 10.1080/15287394.2012.625546.22047160
Mumtaz M, Fisher J, Blount B, 2012b. Application of physiologically based pharmacokinetic models in chemical risk assessment. J Toxicol 2012:904603. 10.1155/2012/904603.22523493
Muttray A, Klimek L, Faas M, 1999. The exposure of healthy volunteers to 200 ppm 1,1,1-trichloroethane increases the concentration of proinflammatory cytokines in nasal secretions. Int Arch Occup Environ Health 72:485–488.10541915
Muttray A, Kurten R, Jung D, 2000. Acute effects of 200 ppm 1,1,1-trichloroethane on the human egg. Eur J Med Res 5:375–384. Myhr BC, Caspary WJ. 1988. Evaluation of the L5178Y mouse lymphoma cell mutagenesis assay: Intralaboratory results for sixty-three coded chemicals tested at Litton Bionetics, Inc. Environ Mol Mutagen 12:103–194.
Nagao M, Takahashi Y. 1981. Mutagenic activity of 42 coded compounds in the Salmonella/microsome assay. Prog Mutat Res 1:302–313.
Nagatoshi H, Itoh I, Takeda S. 1994. [Determination of urinary metabolites of organic solvents among chemical industry workers]. Sangyo Igaku 36(2):106–113. 10.1539/joh1959.36.2_106. (Japanese)8007432
Nakahama T, Sarutani S, Inouye Y. 2000. Effects of tetrachloroethylene and 1,1,1-trichloroethane on the expression of P450 isoforms in rat lung and liver. J Health Sci 46(1):21–28.
Nakamura S, Oda Y, Shimada T, 1987. SOS-inducing activity of chemical carcinogens and mutagens in Salmonella typhimurium TA1535/pSK1002: Examination with 151 chemicals. Mutat Res 192:239–246.3317033
Namkung E, Rittmann BE. 1987. Estimating volatile organic compound emissions from publicly owned treatment works. J Water Pollut Control Fed 59(7):607–678.
NAS/NRC. 1989. Report of the oversight committee. In: Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press,
NAS/NRC. 2006. Human biomonitoring for environmental chemicals. Washington, DC: The National Academies Press, National Research Council. 10.17226/11700.
NCI. 1977. Bioassay of 1,1,1-trichloroethane for possible carcinogenicity: CAS No. 71–55-6. National Cancer Institute. NCI-CG-TR-3. PB265082.
Nestmann ER, Lee EG H, Matula TI, 1980. Mutagenicity of constituents identified in pulp and paper mill effluents using the Salmonella/mammalian-microsome assay. Mutat Res 79:203–212.7012602
Nestmann ER, Otson R, Kowbel DJ, 1984. Mutagenicity in a modified Salmonella assay of fabric-protecting products containing 1,1,1-trichloroethane. Environ Mutagen 6(1):71–80. 10.1002/em.2860060109.6692801
Neta G, Stewart PA, Rajaraman P, 2012. Occupational exposure to chlorinated solvents and risks of glioma and meningioma in adults. Occup Environ Med 69(11):793–801. 10.1136/oemed-2012-100742.22864249
Niklasson M, Tham R, Larsby B, 1993. Effects of toluene, styrene, trichloroethylene, and trichloroethane on the vestibulo- and opto-oculo motor system in rats. Neurotoxicol Teratol 15(5):327–334. 10.1016/0892-0362(93)90034-l.8277926
Nilsson KB. 1986a. Effects of 1,1,1-trichloroethane on the cGMP metabolism in mouse brain. Acta Pharmacol Toxicol 58:318–326.
Nilsson KB. 1986b. Actions of 1,1,1-trichloroethane on the cAMP metabolism in mouse brain. Acta Pharmacol Toxicol 59:362–369.
NIOSH. 1975. 1,1,1-Trichloroethane: development of a biological standard for the industrial worker by breath analysis. Cincinnati, OH: National Institute for Occupational Safety & Health. PB82151879. NIOSH-00080666. HSM-99–72-84. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB82151879.xhtml. September 27, 2023.
NIOSH. 2018. Chloroethanes. Appendix C - Supplementary exposure limits. NIOSH pocket guide to chemical hazards. National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/nengapdxc.html. September 18, 2023.
NIOSH. 2019. Methyl chloroform. NIOSH pocket guide to chemical hazards. National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgd0404.html. September 18, 2023.
Nishikawa H, Katami T, Yasuhara K. 1993. Contribution of an industrial waste incinerator to the atmospheric concentrations of volatile chlorinated organic compounds. Chemosphere 27(8):1425–1432.
Nishikawa H, Katami T, Takahara Y, 1992. Emission of organic compounds by combustion of waste plastics involving vinyl chloride polymer. Chemosphere 25(12):1953–1960.
NLM. 2023. 1,1,1-Trichloroethane. PubChem. U.S. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/7271. December 19, 2019.
Nolan RJ, Freshour NL, Rick DL, 1984. Kinetics and metabolism of inhaled methyl chloroform (1,1,1-trichloroethane) in male volunteers. Fundam Appl Toxicol 4:654–662.6479512
Nong A, Krishnan K. 2007. Estimation of interindividual pharmacokinetic variability factor for inhaled volatile organic chemicals using a probability-bounds approach. Regul Toxicol Pharmacol 48(1):93–101. 10.1016/j.yrtph.2007.01.008.17367907
Northfield RR. 1981. Avoidable deaths due to acute exposure to 1,1,1-trichloroethane. J Soc Occup Med 31:164–166.7329041
NTP. 1988a. Developmental toxicity evaluation of 1,1,1-trichloroethane (CAS no. 71–55-6) administered to CD rats. Final report part 1. Research Triangle Park, NC: National Toxicology Program. PB88131321. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB88131321.xhtml. September 27, 2023.
NTP. 1988b. Developmental toxicity evaluation of 1,1,1-trichloroethane (CAS No. 71–55-6) administered to CD rats. Final report part 2. Research Triangle Park, NC: National Toxicology Program. PB88134101. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB88134101.xhtml. September 27, 2023.
NTP. 1996. NTP technical report on renal toxicity studies of selected halogenated ethanes administered by gavage to F344/N rats. National Toxicology Program. NIH 96–3935. NTP-TR-45. https://ntp.niehs.nih.gov/publications/reports/tox/000s/tox045. September 27, 2023.
NTP. 2000. NTP technical report on the toxicity studies of 1,1,1-trichloroethane administered in microcapsules in feed to F344/N rats and B6C3F1 mice. U.S. Department of Health and Human Services, National Toxicology Program. NTP-TR-41. NIH 00–4402.
NTP. 2013. Draft OHAT approach for systematic review and evidence integration for literature-based health assessments – February 2013. National Toxicology Program, Office of Health Assessment and Translation. https://ntp.niehs.nih.gov/ntp/ohat/evaluationprocess/draftohatapproach_february2013.pdf. September 27, 2023.
NTP. 2015. OHAT risk of bias rating tool for human and animal studies. Office of Health Assessment and Translation. National Toxicology Program. https://ntp.niehs.nih.gov/ntp/ohat/pubs/riskofbiastool_508.pdf. March 19, 2019.
NTP. 2021. CASRN index. In: Report on carcinogens. 15th ed. National Toxicology Program, https://ntp.niehs.nih.gov/pubhealth/roc/index-1.html#P. January 10, 2022.
O'Callaghan JP, Sriram K. 2005. Glial fibrillary acidic protein and related glial proteins as biomarkers of neurotoxicity. Expert Opin Drug Saf 4(3):433–442. 10.1517/14740338.4.3.433.15934851
Ogata M, Hasegawa T. 1981. Effects of chlorinated aliphatic hydrocarbons on mitochondrial oxidative phosphorylation in the rat with reference to the effects of chlorinated aromatic hydrocarbons. Ind Health 19:71–75.7263304
Ohnishi M, Umeda Y, Katagiri T, 2013. Inhalation carcinogenicity of 1, 1, 1-trichloroethane in rats and mice. Inhal Toxicol 25(5):298–306. 10.3109/08958378.2013.780116.23614731
O'Neil MJ. 2013. 1,1,1-Trichloroethane. In: The Merck index: an encyclopedia of chemicals, drugs, and biologicals. 15th ed. Cambridge, UK: Royal Society of Chemistry, Online.
Ong CN, Koh D, Foo SC, 1993. Volatile organic solvents in correction fluids: Identification and potential hazards. Bull Environ Contam Toxicol 50(6):787–793. 10.1007/BF00209939.8495053
Ono Y, Somiya I, Kawamura M. 1991. The evaluation of genotoxicity using DNA repairing test for chemicals produced in chlorination and ozonation processes. Water Sci Technol 23:329–338.
OSHA. 2021a. Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z-2. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. https://www.govinfo.gov/content/pkg/CFR-2021-title29-vol6/pdf/CFR-2021-title29-vol6-sec1910–1000.pdf. August 28, 2022.
OSHA. 2021b. Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. https://www.govinfo.gov/content/pkg/CFR-2021-title29-vol7/pdf/CFR-2021-title29-vol7-sec1915–1000.pdf. August 28, 2022.
OSHA. 2021c. Safety and health regulations for construction. Subpart D - Occupational health and environment controls. Gases, vapors, fumes, dusts, and mists. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55. https://www.govinfo.gov/content/pkg/CFR-2021-title29-vol8/pdf/CFR-2021-title29-vol8-sec1926-55.pdf. August 28, 2022.
Otson R. 1987. Purgeable organics in Great Lakes raw and treated water. Int J Environ Anal Chem 31:41–53.
Páez-Martinez N, Cruz SL, Lopez-Rubalcava C. 2003. Comparative study of the effects of toluene, benzene, 1,1,1-trichloroethane, diethyl ether, and flurothyl on anxiety and nociception in mice. Toxicol Appl Pharmacol 193:9–16. 10.1016/s0041-008x(03)00335-1.14613712
Páez‐Martinez N, Ambrosio E, García‐Lecumberri C, 2008. Toluene and TCE decrease binding to mu-opioid receptors, but not to benzodiazepine and NMDA receptors in mouse brain. Ann N Y Acad Sci 1139(1):390–401. 10.1196/annals.1432.031.18991886
Parry JM, Sharp DC. 1981. Induction of mitotic aneuploidy in the yeast strain D6 by 42 coded compounds. Prog Mutat Res 1:468–480.
Parsons F, Lage GB. 1985. Chlorinated organics in simulated groundwater environments. J Am Water Works Assoc 77:52–59.
Parsons F, Lage GB, Rice R. 1985. Biotransformation of chlorinated organic solvents in static microcosms. Environ Toxicol Chem 4:739–742.
Pedrozo MF, Siqueira ME. 1996. [Spectrophotometric and gas chromatographic analysis of trichloroacetic acid in urine]. Rev Saude Publica 30(3):261–266. 10.1590/s0034-89101996000300009. (Portuguese)9110472
Pellizzari ED, Zelon HS, Bursey JT, 1984. Sampling and analysis design for volatile halocarbons in indoor and outdoor air. In: Indoor air: Chemical characterization and personal exposure. Vol. 4. Stockholm, Sweden: Swedish Council for Building Research, 203–208.
Penman BW, Crespi CL. 1987. Analysis of human lymphoblast mutation assays by using historical negative control data bases. Environ Mol Mutagen 10:35–60.3691486
Peoples RW, Weight FF. 1994. Trichloroethanol potentiation of gamma-aminobutyric acid-activated chloride current in mouse hippocampal neurones. Br J Pharmacol 113(2):555–563. 10.1111/j.1476-5381.1994.tb17025.x.7834208
Peoples RW, Lovinger DM, Weight FF. 1990. Inhibition of excitatory amino acid currents by general anesthetic agents. Soc Neurosci Abstr 16:1017.
Perry PE, Thomson EJ. 1981. Evaluation of the sister chromatid exchange method in mammalian cells as a screening system for carcinogens. Prog Mutat Res 1:560–569.
Pezzagno G, Imbriani M, Ghittori S, 1986. Relationship between environmental concentrations, respiratory absorption, and urinary concentrations of some solvents: Effects of the work load. G Ital Med Lav 8:109–117.3452554
Pincince AB. 1988. Discussion of: Estimating volatile organic compound emissions from publicly owned treatment works. J Water Pollut Control Fed 59:119–121.
Pise VM, Reigle TG, Muralidhara S, 1998. Effects of acute inhalation exposure to 1,1,1-trichloroethane on the hypothalamo-pituitary-adrenal axis in male Sprague-Dawley rats. J Toxicol Environ Health 54:193–208.
Piwoni MD, Wilson JT, Walters DM, 1986. Behavior of organic pollutants during rapid-infiltration of wastewater into soil. I. Processes, definition, and characterization using a microcosm. Haz Waste Haz Mater 3(1):43–55.
Plaa GL. 1986. Toxic responses of the liver. In: Klassen CD, Amdur MO, Doull J, eds. Casarett and Doull's toxicology: The basic science of poisons. 3rd ed. New York: Macmillan Publishing Company, 236–309.
Plaa GL. 1988. Experimental evaluation of haloalkanes and liver injury. Fundam Appl Toxicol 10:563–570.3294072
Platt DS, Cockrill BL. 1969. Biochemical changes in rat liver in response to treatment with drugs and other agents- II: Effects of halothane, DDT, other chlorinated hydrocarbons, dimethylnitrosamine and ethionine. Biochem Pharmacol 18:445–457. 10.1016/0006-2952(69)90221-4.4305095
Plumacher J, Renner I. 1993. Determination of volatile chlorinated hydrocarbons and trichloroacetic acid in conifer needles by headspace gas chromatography. Fresenius J Anal Chem 347:129–135.
Plumb RH. 1987. A comparison of ground water monitoring data from CERCLA and RCRA sites. Ground Water Monit Remediat 7:94–100.
Poet TS, Thrall KD, Corley RA, 2000. Utility of real time breath analysis and physiologically based pharmacokinetic modeling to determine the percutaneous absorption of methyl chloroform in rats and humans. Toxicol Sci 54:42–51.10746930
Pohl HR, Scinicariello F. 2011. The impact of CYP2E1 genetic variability on risk assessment of VOC mixtures. Regul Toxicol Pharmacol 59(3):364–374. 10.1016/j.yrtph.2011.01.013.21295098
Poulin P, Krishnan K. 1995. A biologically-based algorithm for predicting human tissue: blood partition coefficients of organic chemicals. Hum Exp Toxicol 14(3):273–280.7779458
Prendergast JA, Jones RA, Lenkins LJ, 1967. Effects on experimental animals of long-term inhalation of trichloroethylene, carbon tetrachloride, 1,1,1-trichloroethane dichlorodifluoromethane, and 1,1-dichloroethylene. Toxicol Appl Pharmacol 10:270–289. 10.1016/0041-008x(67)90110-x.4962252
Price PJ, Hassett CM, Mansfield JI. 1978. Transforming activities of trichloroethylene and proposed industrial alternatives. In Vitro 14(3):290–293.669729
Price PS, Conolly RB, Chaisson CF, 2003. Modeling interindividual variation in physiological factors used in PBPK models of humans. Crit Rev Toxicol 33(5):469–503.14594104
Priestly BG, Plaa GL. 1976. Hepatic function after acute or subchronic nicotine administration in untreated mice and mice treated with hepatotoxic chemicals. Arch Int Pharmacodyn Ther 233:132–141.
Prinn R, Cunnold D, Rasmussen R, 1987. Atmospheric trends in methylchloroform and the global average for the hydroxyl radical. Science 238:945–950.17829360
Prinn R, Cunnold D, Simmonds P, 1992. Global average concentration and trend for hydroxyl radicals deduced from ALE/GAGE trichloroethane (methyl chloroform) data for 1978–1990. J Geophys Res 97(D2):2445–2461.
Purdue MP, Stewart PA, Friesen MC, 2017. Occupational exposure to chlorinated solvents and kidney cancer: a case-control study. Occup Environ Med 74(4):268–274. 10.1136/oemed-2016-103849.27803178
Quast JF, Calhoun LL, Frauson LE. 1988. 1,1,1-Trichloroethane formulation: A chronic inhalation toxicity and oncogenicity study in Fischer 344 rats and B6C3F1 mice. Fundam Appl Toxicol 11:611–625. 10.1016/0272-0590(88)90125-x.3229586
Quillardet P, de Bellecombe C, Hofnung M. 1985. The SOS chromotest, a colorimetric bacterial assay for genotoxins: Validation study with 83 compounds. Mutat Res 147:79–95.3889610
Radican L, Wartenberg D, Rhoads GG, 2006. A retrospective occupational cohort study of endstage renal disease in aircraft workers exposed to trichloroethylene and other hydrocarbons. J Occup Environ Med 48(1):1–12. 10.1097/01.jom.0000190300.51629.e0.16404204
Ramsey JC, Andersen ME. 1984. A physiologically based description of the inhalation pharmacokinetics of styrene in rats and humans. Toxicol Appl Pharmacol 73:159–175.6710512
Rane A, Wilkinson GR, Shand DG. 1977. Prediction of hepatic extraction ratio from in vitro measurement of intrinsic clearance. J Pharmacol Exp Ther 200(2):420–424.839445
Rank J, Nielsen MH. 1994. Evaluation of the Allium anaphase-telophase test in relation to genotoxicity screening of industrial wastewater. Mutat Res 312:17–24.7507212
Ranson FL, Berry PJ. 1986. Death associated with the abuse of typewriter correction fluid. Med Sci Law 26(4):308–310.3784854
Rasmussen R, Khalil M, Hoyt S. 1982. Trace gases in snow and rain. In: Proceedings of the 4th International Conference. Precipitation scavenging, dry deposition, and resuspension. Elsevier Science Publishing Co., Inc, 1301–1314.
Rastogi SC. 1992. Headspace analysis of chlorinated organic solvents in aerosol cans by gas chromatography. Chromatographia 33(3/4):117–121.
Rastogi SC. 1993. Organic solvent levels in model and hobby glues. Bull Environ Contam Toxicol 51(4):501–507. 10.1007/BF00192164.8400651
Raymer JH, Pellizzari ED, Thomas KW, 1991. Elimination of volatile organic compounds in breath after exposure to occupational and environmental microenvironments. J Expos Anal Environ Epidemiol 1(4):439–452.
Reid JB, Muianga CV. 2012. Saturated halogenated aliphatic hydrocarbons two to four carbons. In: Bingham E, Cohrssen B, eds. Patty's toxicology. New York, NY: Wiley, 61–127.
Reinhardt CF, Mullin LS, Maxfield ME. 1973. Epinephrine-induced cardiac arrhythmia potential of some common industrial solvents. J Occup Med 15(12):953–955.4763670
Reist PC, Rex F. 1977. Odor detection and respirator cartridge replacement. Am Ind Hyg Assoc J 38:563–566.920603
Reitz RH, McDougal JN, Himmelstein MW, 1988. Physiologically based pharmacokinetic modeling with methylchloroform: Implications for interspecies, high dose/low dose, and dose route extrapolations. Toxicol Appl Pharmacol 95:185–199.3420611
RePORTER. 2023. 1,1,1-Trichloroethane. Research Portfolio Online Reporting Tools. National Institutes of Health. https://reporter.nih.gov/. September 18, 2023.
Richold M, Jones E. 1981. Mutagenic activity of 42 coded compounds in the Salmonella/microsome assay. Prog Mutat Res 1:314–322.
Riihimäki V, Pfäffli P. 1978. Percutaneous absorption of solvent vapors in man. Scand J Work Environ Health 4:73–85.644269
Robbiano L, Mereto E, Morando AM, 1998. Increased frequency of micronucleated kidney cells in rats exposed to halogenated anaesthetics. Mutat Res 413:1–6.9602852
Rogers SE, Peterson DL, Lauer WC. 1987. Organic contaminants removal for potable reuse. J Water Pollut Control Fed 59(7):722–732.
Rohr Indus Inc. 1986. Attachment II. Background information. Tab 1. Mortality study of Rohr employees final report. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0535753. 88–920001057. 8EHQ-0292–2416.
Rohr Indus Inc. 1987. Initial submission: Letter reviewing a mortality study of Rohr Indus Inc. employees with attachments and cover letter dated 022692. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0535753. 88–920001057. 8EHQ-0292–2416.
Roldan-Arjona T, Garcia-Pedrajas MD, Luque-Romero FL, 1991. An association between mutagenicity of the Ara test of Salmonella typhimurium and carcinogenicity in rodents for 16 halogenated aliphatic hydrocarbons. Mutagenesis 6(3):199–205.1881351
Rooney AA, Boyles AL, Wolfe MS, 2014. Systematic review and evidence integration for literature-based environmental health science assessments. Environ Health Perspect 122(7):711–718. 10.1289/ehp.1307972.24755067
Rosengren LE, Aurell A, Kjellstrand P, 1985. Astrogliosis in the cerebral cortex of gerbils after long-term exposure to 1,1,1-trichloroethane. Scand J Work Environ Health 11:447–455. 10.5271/sjweh.2201.4095523
Rosenkranz HS, Hyman J, Leifer Z. 1981. DNA polymerase deficient assay. Prog Mutat Res 1:210–218.
Rowland I, Severn B. 1981. Mutagenicity of carcinogens and noncarcinogens in the Salmonella/microsome test. Prog Mutat Res 1:323–332.
RTI. 1987. Absorption, disposition, metabolites, and excretion of 1,1,1-trichloroethane (TCEN). Research Triangle Park: National Institute of Environmental Health by Research Triangle Institute. RTI213/311T-3662.
Ruder AM, Yiin JH, Waters MA, 2013. The Upper Midwest Health Study: gliomas and occupational exposure to chlorinated solvents. Occup Environ Med 70(2):73–80. 10.1136/oemed-2011-100588.23104734
Ruiz P, Ray M, Fisher J, 2011. Development of a human physiologically based pharmacokinetic (PBPK) Toolkit for environmental pollutants. Int J Mol Sci 12(11):7469–7480. 10.3390/ijms12117469.22174611
Salamone MH, Heddle JA, Katz M. 1981. Mutagenic activity of 41 compounds in the in vivo micronucleus assay. In: de Serres FJ, Ashby J, eds. Evaluation of short-term tests for carcinogens: Report of the International Collaborative Program. Progress in Mutation Research. New York, NY: Elsevier, 686–697.
Sallmen M, Lindbohm M, Anttila A, 1998. Time to pregnancy among the wives of men exposed to organic solvents. Occup Environ Med 55:24–30. 10.1136/oem.55.1.24.9536159
Salvini M, Binaschi S, Riva M. 1971. Evaluation of the psychophysiological functions in humans exposed to the 'threshold limit value' of 1,1,1-trichloroethane. Br J Ind Med 28(3):286–292. 10.1136/oem.28.3.286.5557849
Savolainen H, Pfaffli P, Tengen M, 1977. Trichloroethylene and 1,1,1-trichloroethane: Effects on brain and liver after five days intermittent inhalation. Arch Toxicol 38(3):229–237. 10.1007/BF00293657.578726
Savolainen K, Riihimaki V, Laine A, 1981. Short-term exposure of human subjects to m-xylene and 1,1,1-trichloroethane. Int Arch Occup Environ Health 49:89–98. 10.1007/BF00380813.7298217
Sax NI, Lewis RJ. 1987. 1,1,1-Trichloroethane. In: Hawley's condensed chemical dictionary. 11 ed. New York, NY: Van Nostrand Reinhold Company, 1176.
Schairer LA, Sautkulis RC, Tempel NR. 1983. A search for the identity of genotoxic agents in the ambient air using the Tradescantia bioassay. Environ Sci Res 27:211–228.
Schumann AM, Fox TR, Watanabe PG. 1982. [14C]Methyl chloroform (1,1,1-trichloroethane): pharmacokinetics in rats and mice following inhalation exposure. Toxicol Appl Pharmacol 62(3):390–401. 10.1016/0041-008x(82)90140-5.7071857
Schwetz BA, Leong BK J, Gehring PJ. 1975. The effect of maternally inhaled trichloroethylene, perchloroethylene, methyl chloroform, and methylene chloride on embryonal and fetal development in mice and rats. Toxicol Appl Pharmacol 32:84–96. 10.1016/0041-008x(75)90197-0.1135881
Seki Y, Urashima Y, Aikawa H, 1975. Trichloro-compounds in the urine of humans exposed to methyl chloroform at sub-threshold levels. Int Arch Arbeitsmed 34(1):39–49. 10.1007/BF00538927.1132907
Sharp DC, Parry JM. 1981a. Induction of mitotic gene conversion by 41 coded compounds using the yeast culture JD1. Prog Mutat Res 1:491–501.
Sharp DC, Parry JM. 1981b. Use of repair-deficient strains of yeast to assay the activity of 40 coded compounds. Prog Mutat Res 1:502–516.
Shen TT. 1982. Estimation of organic compound emissions from waste lagoons. J Air Pollut Control Assoc 32(1):79–82.
Shimada Y. 1988. [Studies on monochlorobenzene poisoning. 3. Distribution of monochlorobenzene in the organs of pregnant mice and its transfer to the fetus through the placenta: Comparison with trichloroethylene and 1,1,1-trichloroethane]. Okayama Igakkai Zasshi 100(1):147–153. (Japanese)
Silverstein MA. 1983. Letter to the Editor. Arch Environ Health 38:252.6615008
Simmon VF, Shepherd GF. 1981. Mutagenic activity of 42 coded compounds in the Salmonella/microsome assay. Prog Mutat Res 1:333–342.
Simmon VF, Kauhanen K, Tardiff RG. 1977. Mutagenic activity of chemicals identified in drinking water. Dev Toxicol Environ Sci 2:249–258.
Simpson IJ, Blake NJ, Blake DR, 2007. Strong evidence for negligible methyl chloroform (CH3CCl3) emissions from biomass burning. Geophys Res Lett 34:L10805. 10.1029/2007GL029383.
Singh HB, Salas L, Viezee W, 1992. Measurement of volatile organic chemicals at selected sites in California. Atmos Environ 26(16):2929–2946.
Skopek TR, Andon BM, Kaden DA, 1981. Mutagenic activity of 42 coded compounds using 8-azaguanine resistance as a genetic marker in Salmonella typhimurium. Prog Mutat Res 1:371–375.
Solomon S, Albritton DL. 1992. Time-dependent ozone depletion potentials for short- and long-term forecasts. Nature 357:33–37.
Spence JW, Hanst PL. 1978. Oxidation of chlorinated ethanes. J Air Pollut Control Assoc 38(3):250–253.
Spencer PJ, Albee RR, Mattsson JL, 1990. Acute neurophysiologic effects of 1,1,1-trichloroethane via gavage in rats. Final report. Letter submitting information on acute motor activity and acute neurophysiology studies required by the 1,1,1-trichloroethane consent order with attachments. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0533134. 40–9124602. 47004 N3–2. Study ID: K-001716–090C. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0533134.xhtml. September 27, 2023.
Spirtas R, Stewart PA, Lee JS, 1991. Retrospective cohort mortality study of workers at an aircraft maintenance facility. I. Epidemiological results. Br J Ind Med 48(8):515–530. 10.1136/oem.48.8.515.1878308
Stahl CJ, Fatteh AV, Dominguez AM. 1969. Trichloroethane poisoning: Observations on the pathology and toxicology in six fatal cases. J Forensic Sci 14(3):393–397.5802949
Stewart RD. 1971. Methyl chloroform intoxication: Diagnosis and treatment. JAMA 215(11):1789–1792.5107711
Stewart RD, Dodd HC. 1964. Absorption of carbon tetrachloride, trichloroethylene, tetrachloroethylene, methylene chloride, and 1,1,1-trichloroethane through the human skin. Ind Hyg J 25:439–446.
Stewart RD, Andrews JT. 1966. Acute intoxication with methylchloroform. JAMA 195(11):904–906.5951961
Stewart RD, Gay HH, Erley DS, 1961. Human exposure to 1,1,1-trichloroethane vapor: Relationship of expired air and blood concentrations to exposure and toxicity. Am Ind Hyg Assoc J 22:252–262. 10.1080/00028896109343404.
Stewart RD, Gay HH, Schaffer AW, 1969. Experimental human exposure to methyl chloroform vapor. Arch Environ Health 19:467–472. 10.1080/00039896.1969.10666870.5822992
Styles JA. 1981. Activity of 42 coded compounds in the BHK-21 cell transformation test. Prog Mutat Res 1:638–646.
Sullivan LJ. 1994. Construction fatality: Application of a concrete sealant. Appl Occup Environ Hyg 9(10):681–682.
Suovaniemi O, Ekholm P, Falck K, 1985. An automated analysis system for bacterial mutagenicity assays. Amer Lab 17:122, 124–129.
Swan SH, Shaw G, Harris JA, 1989. Congenital cardiac anomalies in relation to water contamination, Santa Clara County, California, 1981–1983. Am J Epidemiol 129(5):885–893. 10.1093/oxfordjournals.aje.a115222.2784935
Swann RL, Laskowski DA, McCall PJ, 1983. A rapid method for the estimation of the environmental parameters octanol/water partition coefficient, soil sorption constant, water to air ratio, and water solubility. In: Gunther FA, Gunther JD, eds. Residue reviews: Residues of pesticides and other contaminants in the total environment. Vol. 85. New York, NY: Springer-Verlag, 17–28. 10.1007/978-1-4612-5462-1_3.
Sweeney LM, Gearhart JM. 2020. Examples of physiologically based pharmacokinetic modeling applied to risk assessment. In: Fisher JW, Gearhart JM, Lin Z, eds. Physiologically based pharmacokinetic (PBPK) modeling. Academic Press: 281–299. 10.1016/B978-0-12-818596-4.00011-4.
Tabak HH, Quave SA, Mashni CI, 1981. Biodegradability studies with organic priority pollutant compounds. J Water Pollut Control Fed 53:1503–1518.
Takahara K. 1986a. [Experimental study on toxicity of trichloroethane. Part 3. Changes in liver function of mice after exposure to 1,1,1- and 1,1,2-trichloroethane]. Okayama Igakkai Zasshi 98(11–12):1099–1109. 10.4044/joma1947.98.11-12_1099. (Japanese)
Takahara K. 1986b. [Experimental study on toxicity of trichloroethane. Part 1. Organ distribution of 1,1,1- and 1,1,2-trichloroethanes in exposed mice]. Okayama Igakkai Zasshi 98:1079–1089. (Japanese)
Taketomo AP, Grimsrud E. 1977. An analysis of halocarbons in the air of several working and living environments. Proc Mont Acad Sci 37:128–134.
Talibov M, Auvinen A, Weiderpass E, 2017. Occupational solvent exposure and adult chronic lymphocytic leukemia: No risk in a population-based case-control study in four Nordic countries. Int J Cancer 141(6):1140–1147. 10.1002/ijc.30814.28571111
Talukdar RK, Mellouki A, Schmoltner AM, 1992. Kinetics of the OH reaction with methyl chloroform and its atmospheric implications. Science 257:227–230.17794755
Tan YM, Chan M, Chukwudebe A, 2020. PBPK model reporting template for chemical risk assessment applications. Regul Toxicol Pharmacol 115:104691. 10.1016/j.yrtph.2020.104691.32502513
Taningher M, Parodi S, Grilli S, 1991. Lack of correlation between alkaline DNA fragmentation and DNA covalent binding induced by polychloroethanes after in vivo administration. Problems related to the assessment of a carcinogenic hazard. Cancer Detect Prev 15(1):35–39.2044072
Tardif R, Charest-Tardif G. 1999. The importance of measured end-points in demonstrating the occurrence of interactions: A case study with methylchloroform and m-xylene. Toxicol Sci 49:312–317.10416277
Taskinen H, Anttila A, Lindbohm ML, 1989. Spontaneous abortions and congenital malformations among the wives of men occupationally exposed to organic solvents. Scand J Work Environ Health 15:345–352. 10.5271/sjweh.1839.2799322
Tay P, Pinnagoda J, Sam CT, 1995. Environmental and biological monitoring of occupational exposure to 1,1,1-trichloroethane. Occup Med (Lond) 45(3):147–150. 10.1093/occmed/45.3.147.7605977
Texter EC, Grunow WA, Zimmerman HJ. 1979. Centrizonal necrosis of the liver from alpha trichloroethane followed by chronic active liver disease with recovery and Budd-Chiari syndrome [abstract]. Clin Res 27:684.
Thomas RS, Bigelow PL, Keefe TJ, 1996. Variability in biological exposure indices using physiologically based pharmacokinetic modeling and Monte Carlo simulation. Am Ind Hyg Assoc J 57:23–32.8588550
Thompson JA, Ho B, Mastovich SL. 1985. Dynamic headspace analysis of volatile metabolites from the reductive dehalogenation of trichloro- and tetrachloroethanes by hepatic microsomes. Anal Biochem 145:376–384.4014669
Thomson JA. 1981. Mutagenic activity of 42 coded compounds in the lambda induction assay. Prog Mutat Res 1:224–235.
Toftgard R, Nilsen OG, Gustafsson J. 1981. Changes in rat liver microsomal cytochrome P-450 and enzymatic activities after the inhalation of n-hexane, xylene, methyl ethyl ketone and methylchloroform for four weeks. Scand J Work Environ Health 7:31–37. 10.5271/sjweh.2569.7313607
Tomicic C, Berode M, Oppliger A, 2011. Sex differences in urinary levels of several biological indicators of exposure: a human volunteer study. Toxicol Lett 202(3):218–225. 10.1016/j.toxlet.2011.01.032.21352904
Torkelson TR, Oyen F, McCollister DD, 1958. Toxicity of 1,1,1-trichloroethane as determined on laboratory animals and human subjects. Am Ind Hyg Assoc J 19:353–362. 10.1080/00028895809343606.13582851
Traiger GJ, Plaa GL. 1974. Chlorinated hydrocarbon toxicity: Potentiation by isopropyl alcohol and acetone. Arch Environ Health 28:276–278.4821771
Travers H. 1974. Death from 1,1,1-trichloroethane abuse: Case report. Mil Med 139:889–890.
TRI21. 2023. Trichloroethylene. TRI explorer: Providing access to EPA’s toxics release inventory data. U.S. Environmental Protection Agency. http://www.epa.gov/triexplorer/. May 31, 2023.
Trueman RW. 1981. Activity of 42 coded compounds in the Salmonella reverse mutation test. Prog Mutat Res 1:343–350.
Truffert L, Girard-Wallon C, Emmerich E, 1977. [Early experimental detection of the hepatotoxicity of some chlorinated solvents by studying the synthesis of hepatic DNA]. Arch Mal Prof 38:261–263. (French)
Tsuchimoto T, Matter BE. 1981. Activity of coded compounds in the micronucleus test. Prog Mutat Res 1:705–711.
Tsuruta H. 1975. Percutaneous absorption of organic solvents. I. Comparative study of the in vivo percutaneous absorption of chlorinated solvents in mice. Ind Health 13:227–236.
Tu AS, Murray TA, Hatch KM, 1985. In vitro transformation of BALB/c-3T3 cells by chlorinated ethanes and ethylenes. Cancer Lett 28(1):85–92. 10.1016/0304-3835(85)90096-5.4027960
Turina MP, Colacci A, Grilli S, 1986. Short-term tests of genotoxicity for 1,1,1-trichloroethane. Res Commun Chem Pathol Pharmacol 52(3):305–320.2426748
Tweats DJ. 1981. Activity of 42 coded compounds in a differential killing test using Escherichia coli strains WP2, WP67 (uvrA polA), and CM871 (uvrA lexA recA). Prog Mutat Res 1:199–209.
Tyson CA, Hawk-Prather K, Story DL, 1983. Correlations of in vitro and in vivo hepatotoxicity for five haloalkanes. Toxicol Appl Pharmacol 70:289–302.6623471
USGS. 2014a. The quality of our Nation's waters - Water quality in principal aquifers of the United States 1991–2010. Reston, VA: U.S. Geological Survey. Circular 1360. https://pubs.usgs.gov/circ/1360/pdf/circ1360report.pdf. September 27, 2023.
USGS. 2014b. Appendix 1–3. The quality of our Nation's waters - Water quality in principal aquifers of the United States 1991–2010. Reston, VA: U.S. Geological Survey. Circular 1360. https://pubs.usgs.gov/circ/1360/appendixes/circ1360appendix1-3.xlsx. September 27, 2023.
USGS. 2019. An update of hydrologic conditions and distribution of selected constituents in water, Eastern Snake River Plain Aquifer and perched groundwater zones, Idaho National Laboratory, Idaho, emphasis 2016–18. Reston, VA: U.S. Geological Survey. 2019–5149. 10.3133/sir20195149.
USGS. 2022. Characterization of ambient groundwater quality within a statewide, fixed-station monitoring network in Pennsylvania, 2015–19. Reston, VA: U.S. Geological Survey. Scientific Investigations Report 2021–5119. 10.3133/sir20215119.
USITC. 2023. Total exports | 2014. U.S. International Trade Commission. https://dataweb.usitc.gov/. August 21, 2023.
Vainio H, Parkki MG, Marniemi J. 1976. Effects of aliphatic chlorohydrocarbons on drug-metabolizing enzymes in rat liver in vivo. Xenobiotica 6(10):599–604.824867
Valcke M, Krishnan K. 2011a. Evaluation of the impact of the exposure route on the human kinetic adjustment factor. Regul Toxicol Pharmacol 59(2):258–269. 10.1016/j.yrtph.2010.10.008.20969910
Valcke M, Krishnan K. 2011b. Assessing the impact of the duration and intensity of inhalation exposure on the magnitude of the variability of internal dose metrics in children and adults. Inhal Toxicol 23(14):863–877. 10.3109/08958378.2011.609918.22084919
Vanlaethem-Meuree N, Wisemberg J, Simon PC. 1979. Ultraviolet absorption spectrum of methylchloroform in the vapor phase. Geophys Res Lett 6(6):451–454.
Vargas C, Ahlert RC. 1987. Anaerobic degradation of chlorinated solvents. J Water Pollut Control Fed 59:964–968.
Venitt S, Crofton-Sleigh C. 1981. Mutagenicity of 42 coded compounds in a bacterial assay using Escherichia coli and Salmonella typhimurium. Prog Mutat Res 1:351–360.
Viola A, Sigon M, Pittoni G, 1981. Serum enzyme activities and histological changes after percutaneous application of methylchloroform. Med Lav 72(5):410–415.7322019
Vogel TM, McCarty PL. 1987. Abiotic and biotic transformations of 1,1,1-trichloroethane under methanogenic conditions. Environ Sci Technol 21:1208–1213.
Vogel EW, Nivard MJ M. 1993. Performance of 181 chemicals in a Drosophila assay predominantly monitoring interchromosomal mitotic recombination. Mutagenesis 8(1):57–81.8450769
Vyskocil A, Leroux T, Truchon G, 2010. Ototoxicity of industrial chemicals alone or in combination with noise: Methyl chloroform. Utilitaires: Otoxicity. Montreal: École de santé publique de l’Université de Montréal. https://espum.umontreal.ca/lespum/departement-de-sante-environnementale-et-sante-au-travail/la-recherche-au-dsest/production-scientifique/utilitaires/otoxicity/. September 27, 2023.
Vyskocil A, Truchon G, Leroux T, 2012. A weight of evidence approach for the assessment of the ototoxic potential of industrial chemicals. Toxicol Ind Health 28(9):796–819. 10.1177/0748233711425067.22064681
Wahlberg JE. 1984a. Erythema-inducing effects of solvents following epicutaneous administration to man - studied by laser Doppler flowmetry. Scand J Work Environ Health 10:159–162.6236553
Wahlberg JE. 1984b. Edema-inducing effects of solvents following topical administration. Derm Beruf Umwelt 32(3):91–94.6468283
Wahlberg JE, Boman A. 1979. Comparative percutaneous toxicity of ten industrial solvents in the guinea pig. Scand J Work Environ Health 5:345–351.538425
Wakeham SG, Goodwin JT, Davis AC. 1983. Distributions and fate of volatile organic compounds in Narragansett Bay, Rhode Island. Can J Fish Aquat Sci 40(S2):s304–s321. 10.1139/f83-336.
Walker BL, Cooper CD. 1992. Air pollution factors for medical waste incinerators. J Air Waste Manage Assoc 42:784–791.
Wallace LA, Zweidinger R, Erickson M, 1982. Monitoring individual exposure: Measurements of volatile organic compounds in breathing-zone air, drinking water and exhaled breath. Environ Int 8:269–282.
Wallace LA, Pellizzari E, Hartwell T, 1984. Analyses of exhaled breath of 355 urban residents for volatile organic compounds. Indoor Air 4:15–20.
Wallace LA, Pellizzari ED, Hartwell TD, 1985. Personal exposures, indoor-outdoor relationships, and breath levels of toxic air pollutants measured for 335 persons in New Jersey. Atmos Environ 19(10):1651–1661.
Wallace LA, Pellizzari E, Hartwell T, 1986. Concentrations of 20 volatile organic compounds in the air and drinking water of 350 residents of New Jersey compared with concentrations in their exhaled breath. J Occup Med 28(8):603–608.3746480
Wallace LA, Pellizari E, Leaderer B, 1987a. Emissions of volatile organic compounds for building materials and consumer products. Atmos Environ 21(2):385–393.
Wallace LA, Hartwell TD, Perritt K, 1987b. The influence of personal activities on exposure to volatile organic compounds. In: Indoor Air '87: proceedings of the 4th International Conference on Indoor Air Quality and Climate, Berlin (West) 17–21 August. Germany: Institute for Water, Soil and Air Hygiene, 2.181–185.
Wallace LA, Pellizzari ED, Hartwell TD, 1987c. The TEAM study: Personal exposures to toxic substances in air, drinking water, and breath of 400 residents of New Jersey, North Carolina, and North Dakota. Environ Res 43(2):290–307. 10.1016/s0013-9351(87)80030-0.3608934
Wallace LA, Pellizzari ED, Hartwell TD, 1988. The California TEAM study: Breath concentrations and personal exposures to 26 volatile compounds in air and drinking water of 188 residents of Los Angeles, Antioch, and Pittsburg, CA. Atmos Environ 22(10):2141–2163.
Wallace LA, Pellizzari ED, Hartwell TD, 1989. The influence of personal activities on exposure to volatile organic compounds. Environ Res 50(1):37–55. 10.1016/S0013-9351(89)80047-7.2792060
Wang R, Nakajima T, Tsuruta H, 1996. Effect of exposure to four organic solvents on hepatic cytochrome P450 isozymes in rat. Chem Biol Interact 99(1–3):239–252. 10.1016/0009-2797(95)03673-3.8620572
Warneck P. 2007. A review of Henry’s law coefficients for chlorine-containing C1 and C2 hydrocarbons. Chemosphere 69(3):347–361. 10.1016/j.chemosphere.2007.04.088.17590409
Warren DA, Reigle TG, Dallas CE. 1997. Effect of single versus repeated exposure to 1,1,1-trichloroethane on rat operant behavior. Int J Toxicol 16:585–598.
Warren DA, Reigle TG, Muralidhara S, 1998. Schedule-controlled operant behavior of rats during 1,1,1-trichloroethane inhalation: Relationship to blood and brain solvent concentrations. Neurotoxicol Teratol 20:143–153.9536460
Weisel CP, Alimokhtari S, Sanders PF. 2008. Indoor air VOC concentrations in suburban and rural New Jersey. Environ Sci Technol 42(22):8231–8238. 10.1021/es8005223.19068799
Whittaker SG, Zimmermann FK, Dicus B, 1990. Detection of induced mitotic chromosome loss in Saccharomyces cerevisiae an interlaboratory assessment of 12 chemicals. Mutat Res 241:225–242.2195333
WHO. 2010. WHO guidelines for indoor air quality: Selected pollutants. World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. April 25, 2012.
WHO. 2022. Guidelines for drinking-water quality. Fourth edition incorporating the first and second addenda. Geneva: World Health Organization. https://www.who.int/publications/i/item/9789240045064. September 18, 2023.
Widdowson EM, Dickerson JW T. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advanced treatise II: The elements. Part A. New York, NY: Academic Press, 1–247.
Wiley JL, Fagalde RE, Buhler KG, 2002. Evaluation of 1,1,1-trichloroethane and flurothyl locomotor effects following diazepam treatment in mice. Pharmacol Biochem Behav 71:163–169.11812519
Williams GM, Mori H, McQueen CA. 1989. Structure-activity relationships in the rat hepatocyte DNA-repair test for 300 chemicals. Mutat Res 221(3):263–286. 10.1016/0165-1110(89)90039-0.2682231
Willmann A, Trautmann AL, Kushmaro A, 2023. Intrinsic and bioaugmented aerobic trichloroethene degradation at seven sites. Heliyon 9(2):e13485. 10.1016/j.heliyon.2023.e13485.36846709
Wilson BH, Pogue DW. 1987. Biological removal of trichloroethylene from contaminated ground water. In: 194th National Meeting of the Environmental Chemistry Division of the American Chemical Society, New Orleans, Louisiana, USA. Chelsea, Michigan: Lewis Publishers, Inc., 628–631.
Wilson JT, McNabb JF, Wilson BH, 1983. Biotransformation of selected organic pollutants in ground water. Dev Ind Microbiol 24:225–233.
Wilson SC, Burnett V, Waterhouse KS, 1994. Volatile organic compounds in digested United Kingdom sewage sludges. Environ Sci Technol 28(2):259–266. 10.1021/es00051a012.22176171
Winek CL, Wahba WW, Huston R, 1997. Fatal inhalation of 1,1,1-trichloroethane. Forensic Sci Int 87:161–165.9237378
Wood PR, Lang RF, Payan IL. 1985. Anaerobic transformation, transport and removal of volatile chlorinated organics in ground water. In: Ward CH, Giger W, McCarty PL, eds. Ground water quality. New York, NY: John Wiley and Sons, Inc., 493–511.
Woolverton WL, Balster RL. 1981. Behavioral and lethal effects of combinations of oral ethanol and inhaled 1,1,1-trichloroethane in mice. Toxicol Appl Pharmacol 59:1–7. 10.1016/0041-008x(81)90446-4.7256748
WQP. 2023. 1,1,1-Trichloroethane. Water quality portal. Advisory Committee on Water Information (ACWI); Agricultural Research Service (ARS); Environmental Protection Agency (EPA); National Water Quality Monitoring Council (NWQMC); United States Geological Survey (USGS). https://www.waterqualitydata.us/portal/. September 28, 2023.
Wrensch M, Swan SH, Lipscomb J, 1990a. Pregnancy outcomes in women potentially exposed to solvent-contaminated drinking water in San Jose, California. Am J Epidemiol 131(2):283–300.2296981
Wrensch M, Swan SH, Murphy PJ, 1990b. Hydrogeologic assessment of exposure to solvent-contaminated drinking water: Pregnancy outcomes in relation to exposure. Arch Environ Health 45:210–216.2400242
Wright MF, Strobl DJ. 1984. 1,1,1-Trichloroethane cardiac toxicity: Report of a case. J Am Osteopath Assoc 84:285–288.6511508
Wu T, Bhanegaonkar AJ, Flowers JW. 2006. Blood concentrations of selected volatile organic compounds and neurobehavioral performance in a population-based sample. Arch Environ Occup Health 61(1):17–25. 10.3200/aeoh.61.1.17-25.17503617
Yao CC D, Haag WR. 1991. Rate constants for direct reactions of ozone with several drinking water contaminants. Water Res 25(7):761–773.
York RG, Sowry BM, Hastings L, 1982. Evaluation of teratogenicity and neurotoxicity with maternal inhalation exposure to methyl chloroform. J Toxicol Environ Health 9:251–266. 10.1080/15287398209530159.7077683
Yoshida K. 1993. Preliminary exposure assessment of volatile chlorinated hydrocarbons in Japan. Chemosphere 27(4):621–630.
Yoshida T, Andoh K, Fukuhara M. 1998. Estimation of absorption of environmental contaminants in low-level exposure by pharmacokinetic analysis. J Toxicol Environ Health A 54(2):145–158. 10.1080/009841098158971.9652550
You L, Dallas CE. 1998. Regional brain dosimetry of trichloroethane in mice and rats following inhalation exposures. J Toxicol Environ Health A 54(4):285–299. 10.1080/009841098158854.9638900
You L, Dallas CE. 2000. Effects of inhaled 1,1,1-trichloroethane on the regional brain cyclic GMP levels in mice and rats. J Toxicol Environ Health A 60(5):331–341. 10.1080/00984100050030118.10912586
You L, Muralidhara S, Dallas CE. 1994. Comparisons between operant response and 1,1,1-trichloroethane toxicokinetics in mouse blood and brain. Toxicology 93:151–163.7974511
Young DR. 1978. Priority pollutants in municipal wastewaters. Annual report [1 Jul 77–31 Dec 78]. South California Coastal Water Project. 103–112. PB299830.
Young DR, Gossett RW, Baird RB, 1983. Wastewater inputs and marine bioaccumulation of priority pollutant organics off Southern California. In: Jolley RL, ed. Water chlorination: Environmental impact health effects, Volume 4: Proceedings of the Fourth Conference on Water Chlorination-Environmental Impact and Health Effects, Pacific Grove, California, October 18–23, 1981. Ann Arbor, MI: Ann Arbor Science, 871–884.
Zimmermann FK, Scheel I. 1981. Induction of mitotic gene conversion in strain D7 of Saccharomyces cerevisiae by 42 coded chemicals. Prog Mutat Res 1:481–490.