# CONTRIBUTORS & REVIEWERS

## CHEMICAL MANAGER TEAM

- Carolyn Harper, Ph.D. (Lead)
  Brittany Szafran, DVM, Ph.D.
  Jennifer Przybyla, Ph.D.
  Kambria Haire, M.P.H., Ph.D.
  Melanie Buser, M.P.H.
  ATSDR, Office of Innovation and Analytics,
  Toxicology Section, Atlanta, GA
- Ryan Klein, Ph.D.
  Kerry Diskin, Ph.D.
  Hannah Derrick, B.S.
  Meghan Lynch, DSc.
  Abt Associates, Rockville, MD
- Claire Heit, Ph.D.
  Julie M. Klotzbach, Ph.D.
  Savannah Sierco, M.S.
  Mario Citra, Ph.D.
  SRC, Inc., North Syracuse, NY

## REVIEWERS

- Interagency Minimal Risk Level Workgroup:
  - Includes ATSDR; National Center for Environmental Health (NCEH); National Institute for Occupational Safety and Health (NIOSH); U.S. Environmental Protection Agency (EPA); National Toxicology Program (NTP).
- Additional reviews for science and/or policy:
  - ATSDR, Office of Community Health Hazard Assessment; ATSDR, Office of Capacity Development and Applied Prevention Science; ATSDR, Office of Science; NCEH, Division of Laboratory Sciences; NCEH, Division of Environmental Health Science and Practice; EPA, Office of Research and Development; EPA, Office of Water.

## PEER REVIEWERS

1. Lawrence H. Lash, Ph.D., Editor, Toxicology and Applied Pharmacology, Editor, Toxicology Reports, Professor, Department of Pharmacology, Wayne State University School of Medicine, 540 East Canfield Avenue, Detroit, Michigan
2. G.A. Shakeel Ansari, Ph.D., Professor Emeritus, Department of Pathology, 2.318 MMNP, University of Texas Medical Branch, Galveston, Texas
3. Jeffrey Fisher, Ph.D., Senior Science Fellow for the Computational Biology, Division of ScitoVation, 100 Capitola Drive, Suite 106, Durham, North Carolina

These experts collectively have knowledge of toxicology, chemistry, and/or health effects. All reviewers were selected in conformity with Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

ATSDR scientists review peer reviewers’ comments and determine whether changes will be made to the profile based on comments. The peer reviewers’ comments and responses to these comments are part of the administrative record for this compound.

The listing of peer reviewers should not be understood to imply their approval of the profile's final content. The responsibility for the content of this profile lies with ATSDR.