# VERSION HISTORY

Date | Description
March 2024 | Final toxicological profile released
January 2023 | Draft for public comment toxicological profile released
July 2006 | Final toxicological profile released
August 1995 | Final toxicological profile released
December 1990 | Final toxicological profile released