# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding 1,1,1-trichloroethane in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for 1,1,1-trichloroethane.

Table 7-1 Regulations and Guidelines Applicable to 1,1,1-Trichloroethane

Agency | Description | Information | Reference
Air
EPA | RfC | | IRIS 2007
| Acute RfCs
| 1 hour | 9 mg/m^3^ (1.6 ppm)
| 4 hours and 8 hours | 7 mg/m^3^ (1.3 ppm)
| 24 hours | 6 mg/m^3^ (1.1 ppm)
| Short-term RfC | 5 mg/m^3^ (0.9 ppm)
| Subchronic RfC | 5 mg/m^3^ (0.9 ppm)
| Chronic RfC | 5 mg/m^3^ (0.9 ppm)
WHO | Air quality guidelines | No data | WHO 2010
Water & Food
EPA | Drinking water standards and health advisories | | EPA 2018a
| 1-Day health advisory (10-kg child) | 100 mg/L
| 10-Day health advisory (10-kg child) | 40 mg/L
| DWEL^a^ | 70 mg/L
| National primary drinking water regulations | | EPA 2009
| MCL | 0.2 mg/L
| MCLG | 0.2 mg/L
| RfD | | IRIS 2007
| Chronic RfD | 2 mg/kg/day
| Subchronic RfD | 7 mg/kg/day
WHO | Drinking water quality guidelines | Not established | WHO 2022
FDA | Substances added to food (formerly EAFUS) | Not listed | FDA 2023
| Allowable level in bottled water | 0.20 mg/L | FDA 2022
Cancer
HHS | Carcinogenicity classification | No data | NTP 2021
EPA | Carcinogenicity classification | No data^b^ | IRIS 2007
IARC | Carcinogenicity classification | Group 2A^c^ | IARC 2022
Occupational
OSHA | PEL (8-hour TWA) for general industry, construction, and shipyards | 350 ppm (1,900 mg/m^3^) | OSHA 2021a, 2021b, 2021c
NIOSH | 15-minute ceiling REL | 350 ppm (1,900 mg/m^3^)^d^ | NIOSH 2019
Emergency Criteria
NIOSH | IDLH | 700 ppm | NIOSH 2019
EPA | AEGLs-air | | EPA 2018c
| AEGL 1^e^
| 10-minute, 30-minute, 60-minute, 4-hour, 8-hour | 230 ppm
| AEGL 2^e^
| 10-minute | 930 ppm
| 30-minute | 670 ppm
| 60-minute | 600 ppm
| 4-hour | 380 ppm
| 8-hour | 310 ppm
| AEGL 3^e^
| 10-minute | 4,200 ppm
| 30-minute | 4,200 ppm
| 60-minute | 4,200 ppm
| 4-hour | 2,700 ppm
| 8-hour | 2,100 ppm
DOE | PACs-air | | DOE 2000
| PAC-1^f^ | 230 ppm
| PAC-2^f^ | 600 ppm
| PAC-3^f^ | 4,200 ppm

a DWEL: A lifetime exposure level, assuming 100% exposure from drinking water, at which adverse, noncarcinogenic health effects would not be expected to occur.

b Inadequate information to assess carcinogenic potential.

c Group 2A: probably carcinogenic to humans.

d NIOSH recommends that 1,1,1-trichloroethane be treated in the workplace with caution because of its structural similarity to four chloroethanes shown to be carcinogenic in animals (NIOSH 2018).

e Definitions of AEGL terminology are available from EPA (2018b).

f Definitions of PAC terminology are available from DOE (2023).

AEGL = acute exposure guideline level; DOE = Department of Energy; DWEL = drinking water equivalent level; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; MCL = maximum contaminant level; MCLG = maximum contaminant level goal; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TWA = time-weighted average; WHO = World Health Organization