# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

1,1,1-Trichloroethane is a man-made chlorinated hydrocarbon chemical that was widely used as a solvent and in metal degreasing. It is a synthetic compound. U.S. production of 1,1,1-trichloroethane was to be cut incrementally as per Section 604 of the Clean Air Act and Montreal Protocol, eventually being completely phased out by January 2002, and cease production by 2012 as a result of ozone depletion agreements from the Montreal Protocol (Kapp 2014). While the Montreal Protocol reduced the production of 1,1,1-trichloroethane, some production does continue with a steady decline in the ambient air levels. Information regarding the chemical identity of 1,1,1-trichloroethane is presented in Table 4-1.

Table 4-1 Chemical Identity of 1,1,1-Trichloroethane

Characteristic | Information | Reference
Chemical name | 1,1,1-Trichloroethane | NLM 2023
Synonym(s) and registered trade name(s) | Methylchloroform; chlorothene; chloroetene; Inhibisol; Aerothene MM; Aerothene TT; Solvent 111; Alpha T | NLM 2022
Chemical formula | C_2_H_3_Cl_3_ | Haynes et al. 2015
SMILES | CC(Cl)(Cl)Cl | NLM 2023
Chemical structure | [image] | NLM 2023
CAS registry number | 71-55-6 | Haynes et al. 2015

CAS = Chemical Abstracts Service; SMILES = simplified molecular-input line-entry system

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

1,1,1-Trichloroethane is a volatile organic compound (VOC). It is slightly soluble in water, and its Henry’s law constant suggests that it is readily volatilized from water. Based on the log K_ow_ and log K_oc_ values, 1,1,1-trichloroethane is expected to have high mobility in soil. With a vapor pressure of 124 mm Hg at 25°C, 1,1,1-trichloroethane exists in the atmosphere in the vapor phase. Information regarding physical and chemical properties of 1,1,1-trichloroethane is presented in Table 4-2.

Table 4-2 Physical and Chemical Properties of 1,1,1-Trichloroethane

Property | Information | Reference
Molecular weight | 133.4 | Haynes et al. 2015
Color | Colorless | NIOSH 2019
Physical state | Liquid | Haynes et al. 2015
Melting point | −30°C | Haynes et al. 2015
Boiling point | 74°C | Haynes et al. 2015
Density at 20°C/4°C | 1.3376 | Haynes et al. 2015
Odor | Mild, chloroform-like | NIOSH 2019
Odor threshold:
Water | No data
Air | 120 ppm | Amoore and Hautala 1983; Reist and Rex 1977
| 500 ppm | Amoore and Hautala 1983; Reist and Rex 1977
Taste threshold | No data
Solubility:
Water at 25°C | 1.29 g/L H_2_O; slightly soluble in H_2_O | Haynes et al. 2015; O’Neil 2013
Organic solvent(s) | Soluble in ethanol and chloroform, miscible in diethyl ether; soluble in acetone, benzene, methanol, carbon tetrachloride, and ether | Haynes et al. 2015; O’Neil 2013
Partition coefficients:
Log K_ow_ | 2.49 | Haynes et al. 2015
Log K_oc_ | 2.03 | Friesel et al. 1984
| 2.02 | Chiou et al. 1979
Vapor pressure at 25°C | 16.5 kPa (123.8 mmHg) | Haynes et al. 2015
Henry’s law constant at 25°C | 0.0163 atm-m^3^/mole | Warneck 2007
Autoignition temperature | 537°C | NLM 2023
Flashpoint | >200°F | NLM 2023
Conversion factors
ppm (v/v) to mg/m^3^ in air (20°C) | 1 ppm = 5.46 mg/m^3^ | NIOSH 2019
mg/m^3^ to ppm (v/v) in air (20°C) | 1 mg/m^3^ = 0.185 ppm | Chiou et al. 1980
Explosive limits | 7.5–12.5% in air | NIOSH 2019