# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. LOAELs for serious health effects (such as irreparable damage to the liver or kidneys, or serious birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substances than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Office of Innovation and Analytics, Toxicology Section, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Office of Innovation and Analytics, Toxicology Section, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S106-5, Atlanta, Georgia 30329-4027.

## 1,1,1-Trichloroethane Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,1,1-Trichloroethane
CAS Numbers: | 71-55-6
Date: | March 2024
Profile Status: | Final
Route: | Inhalation
Duration: | Acute
MRL: | 1 ppm (6 mg/m^3^)
Critical Effect: | Neurological endpoint of decreased performance in psychomotor tests
Reference: | Mackay et al. 1987
Point of Departure: | LOAEL of 175 ppm (950 mg/m^3^); LOAEL_ADJ_ of 119 ppm (650 mg/m^3^)
Uncertainty Factor: | 100
LSE Graph Key: | 3
Species: | Human

MRL Summary: An acute-duration inhalation MRL of 1 ppm (6 mg/m^3^) was derived for 1,1,1-trichloro-ethane based on a neurological endpoint of decreased performance in psychomotor tests in humans administered 1,1,1-trichloroethane via inhalation (Mackay et al. 1987). The MRL is based on a LOAEL of 175 ppm, which was applied to a PBPK model to estimate the 24-hour continuous exposure concentration for exposed humans that would result in the same estimated internal dose. This resulted in an adjusted LOAEL of 119 ppm, which was then divided by a total uncertainty factor of 100 (10 for the use of a LOAEL and 10 for human variability).

Selection of the Critical Effect: A number of studies have evaluated the toxicity of 1,1,1-trichloroethane following acute-duration inhalation exposure, although the majority of the studies with more sensitive endpoints focused on neurological endpoints (Evans and Balster 1993; Gamberale and Hultengren 1973; Mackay et al. 1987; Nilsson 1986b; NIOSH 1975; Stewart et al. 1969). Evans and Balster (1993) observed convulsions in mice after 4 days of 24 hour/day exposure to 500 ppm 1,1,1-trichloroethane, which is regarded as a serious effect. Thus, only effects observed at concentrations <500 ppm were considered for the critical effect. Nilsson (1986b) observed a reduction in brain cyclic guanosine monophosphate (cGMP) at 100 ppm, although these results were only presented graphically and were observed in a mouse model rather than in a human. Human studies are generally preferred to animal studies when available, and both Gamberale and Hultengren (1973) and Mackay et al. (1987) were studies conducted in humans. The data from these human studies suggest that decreased performance in psychomotor tests is the most sensitive endpoint following acute-duration inhalation exposure. A summary of select LOAELs is presented in Table A-1.

Table A-1 Summary of Relevant NOAEL and LOAEL Values Following Acute-Duration Inhalation Exposure to 1,1,1-Trichloroethane

Species | Duration | NOAEL (ppm) | LOAEL (ppm) | Effect | Reference
Neurological effects
Human | 4 exposures 30 minutes/exposure | 239.2 | 338.3 | 12.8% decrease in reaction time, 22.6% decrease in perceptual speed, 9.8% decrease in manual dexterity | Gamberale and Hultengren 1973
Human | 3.5 hours | | 175 | 10–15% decrease in simple reaction time | Mackay et al. 1987
Mouse NS | 4 hours | 50 | 100 | ~33% decrease in brain cGMP | Nilsson 1986b

cGMP = cyclic guanosine monophosphate; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; NS = not specified

Selection of the Principal Study: Mackay et al. (1987) evaluated the neurological and toxicological effects of 1,1,1-trichloroethane inhalation in humans. The LOAEL reported by Mackay et al. (1987) for a 10–15% decrease in simple reaction time was the lowest among the studies evaluating acute-duration inhalation exposure in humans. The Mackay et al. (1987) study was also selected by the EPA for the derivation of an acute-duration inhalation reference concentration (RfC) for 1,1,1-trichloroethane. The same methodology used to derive the acute-duration inhalation RfC was used to derive the acute-duration inhalation MRL.

Summary of the Principal Study:

Mackay CJ, Campbell L, Samuel AM, et al. 1987. Behavioral changes during exposure to 1,1,1-trichloroethane: Time-course and relationship to blood solvent levels. Am J Ind Med 11:223-240.

Twelve male volunteers participated in the experiment. Exposures were to 0, 175, or 350 ppm of 1,1,1-trichloroethane for 3.5 hours. Each volunteer was exposed to all three exposure concentrations in a balanced design, with a minimum of 2 weeks between exposures for any one individual. Test performance was assessed immediately before entering the exposure chamber and 20, 60, 120, and 180 minutes after entry. Tests were conducted for three psychomotor tasks (simple reaction time, choice reaction time, and tracking ability) and two cognitive tasks (syntactic reasoning and concentration). Volunteers also completed a stress-arousal checklist as part of the test battery. Blood levels of 1,1,1-trichloroethane were measured after 0, 20, 60, 120, and 180 minutes of exposure. Statistical analysis of variance to determine the main effects of exposure and duration was performed for the various tests, but pairwise statistical comparisons were not made.

The tests for simple reaction time, choice reaction time and tracking ability all showed impaired psychomotor performance in volunteers exposed to 1,1,1-trichloroethane concentrations of 175 and 350 ppm. Effects were detected as soon as 20 minutes after the start of exposure at both concentrations. The test for simple reaction time appeared to be the most sensitive, exhibiting a 10–15% increase over baseline values. Observed performance changes correlated with 1,1,1-trichloroethane absolute blood levels. Performance in the cognitive tasks was not adversely affected by exposure, and neither was the self-reported mood of the volunteers. None of the subjects complained of headache, discomfort, or nausea.

Selection of the Point of Departure for the MRL: The lowest concentration administered, 175 ppm (950 mg/m^3^), is a LOAEL for neurobehavioral effects. Benchmark dose (BMD) modeling was unable to be performed adequately because the study authors did not provide standard deviations of the means with their results. EPA (2006) used a PBPK model by Reitz et al. (1988) to estimate the internal dose in humans exposed to 950 mg/m^3^ 1,1,1-trichloroethane for 1 hour. The estimated internal dose is 1.33 mg/L.

Adjustment for Intermittent Exposure: The Reitz et al. (1988) model was used to estimate the 24-hour continuous exposure concentration that achieves the estimated internal dose of 1.33 mg/L. The resulting LOAELADJ is 119 ppm (650 mg/m^3^).

Uncertainty Factor: The LOAEL_ADJ_ is divided by a total uncertainty factor of 100:

- 10 for use of a LOAEL
- 10 for human variability
  MRL = LOAEL ÷ uncertainty factors
  119 ppm ÷ (10 x 10) = 1.19 ppm (6.497 mg/m^3^) ≈ 1 ppm (6 mg/m^3^)

Other Additional Studies or Pertinent Information that Lend Support to this MRL: EPA derived an acute-duration inhalation RfC for 1,1,1-trichloroethane of 1.1 ppm for a 24-hour exposure based on the Mackay et al. (1987) study. Gamberale and Hultengren (1973) observed psychophysiological test performance deficits in human subjects exposed to 250, 350, 450, and 550 ppm of 1,1,1-trichloroethane in consecutive 30-minute periods. All tasks tested were affected, including simple reaction time, choice reaction time, and tests for manual dexterity and perceptual speed. Statistically significant deficits were found as early as exposure period #2, during which the exposure concentration was 350 ppm. Muttray et al. (1999, 2000) found electroencephalogram changes consistent with increased drowsiness and slight irritant nasal responses in volunteers exposed to 200 ppm. In contrast, no psychomotor effects were seen in volunteers exposed to 1,1,1-trichloroethane vapors at concentrations of 400–450 ppm for 4 hours once or twice in a 24-hour period (Salvini et al. 1971; Savolainen et al. 1981). Laine et al. (1996) found no consistent, statistically significant effects on electroencephalogram, visual-evoked potential, or equilibrium in a group of nine healthy male volunteers exposed to a constant 200 ppm of 1,1,1-trichloro-ethane vapors for 3 hours, followed by a 40-minute lunch break and a 40-minute afternoon exposure. A conservative approach was followed in the selection of Mackay et al. (1987) as the critical study for derivation of an acute-duration inhalation MRL because it identified the lowest LOAEL for psychomotor effects in humans following acute-duration inhalation exposure to 1,1,1-trichloroethane and was supported by results of Gamberale and Hultengren (1973) and Muttray et al. (1999, 2000). The choice of critical effect (neurological changes) is supported by animal studies, although exposure levels eliciting neurobehavioral and neurophysiological effects were much higher than those eliciting psychomotor effects in humans. For example, increased motor activity was observed in mice exposed to 1,250 ppm of 1,1,1-trichloroethane for 30 minutes (Bowen and Balster 1996). A 4-hour exposure of mice to 2,064 ppm resulted in impaired swimming behavior (De Ceaurriz et al. 1983). Dow Chemical (1990) reported 1,1,1-trichloroethane-induced alterations in flash-evoked potential, somatosensory-evoked potential, and electroencephalogram in rats exposed to 1,000 ppm for 6 hours/day on 4 consecutive days.

Agency Contacts (Chemical Managers): Carolyn Harper

## 1,1,1-Trichloroethane Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,1,1-Trichloroethane
CAS Numbers: | 71-55-6
Date: | March 2024
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate
MRL: | 0.7 ppm (4 mg/m^3^)
Critical Effect: | Neurological endpoint of increased GFAP in brain indicative of neuronal damage
Reference: | Rosengren et al. 1985
Point of Departure: | NOAEL of 70 ppm
Uncertainty Factor: | 100
LSE Graph Key: | 74
Species: | Gerbil

MRL Summary: An intermediate-duration inhalation MRL of 0.7 ppm (4 mg/m^3^) was derived for 1,1,1-trichloroethane based on neurological endpoint of increased GFAP in gerbils administered 1,1,1-trichloroethane via continuous inhalation exposure (Rosengren et al. 1985). The MRL is based on a NOAEL of 70 ppm divided by a total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

Selection of the Critical Effect: A number of studies have evaluated the toxicity of 1,1,1-trichloroethane following intermediate-duration inhalation exposure. Prendergast et al. (1967) observed substantial reductions in body weight gain at 380 ppm for both dogs and rabbits when exposed 24 hours/day for 90 days. This exposure resulted in a 51% reduction in body weight gain for dogs and a 66% reduction in body weight gain for rabbits; both of these endpoints are classified as serious LOAELs. Thus, only two studies, Rosengren et al. (1985) and MacEwen and Vernot (1974), observed effects at concentrations <380 ppm; a summary of these LOAELs is presented in Table A-2.

Table A-2 Summary of Relevant NOAEL and LOAEL Values Following Intermediate-Duration Inhalation Exposure to 1,1,1-Trichloroethane

Species | Duration | NOAEL (ppm) | LOAEL (ppm) | Effect | Reference
Neurological effects
Gerbil Mongolian | 3 months 24 hours/day | 70 | 210 (serious LOAEL) | 20% increase in GFAP | Rosengren et al. 1985
Hepatic effects
Mouse NS | 14 weeks 24 hours/day | | 250 | Fatty changes in the liver | MacEwen and Vernot 1974

GFAP = glial fibrillary acid protein; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; NS = not specified

The available data suggest that increased GFAP in the brain is the most sensitive endpoint following intermediate-duration inhalation exposure. In gerbils, a 20% increase in GFAP in the brain was seen at concentrations of 210–1,000 ppm, and a NOAEL of 70 ppm was observed (Rosengren et al. 1985).

Selection of the Principal Study: Rosengren et al. (1985) evaluated neurological and toxicological effects of 1,1,1-trichloroethane inhalation in humans. The NOAEL reported by Rosengren et al. (1985) for an increase in GFAP was the lowest among the studies evaluating intermediate-duration inhalation exposure.

Summary of the Prinicipal Study:

Rosengren LE, Aurell A, Kjellstrand P, et al. 1985. Astrogliosis in the cerebral cortex of gerbils after long-term exposure to 1,1,1-trichloroethane. Scand J Work Environ Health 11:447–455.

Groups of Mongolian gerbils (four/sex) were exposed to 70, 210, or 1,000 ppm of 1,1,1-trichloroethane vapor (cleaning grade, containing 5% dioxane-free stabilizers) continuously for 3 months. Each exposure group was paired with a control group consisting of eight sex-matched littermates of the test group. At the end of the exposure period, all animals were held for 4 months prior to sacrifice. Upon sacrifice, brains were weighed and prepared for analyses for the astroglial proteins, S-100 and GFAP, both of which are biomarkers for astrogliosis. Astrogliosis is the activation of cellular processes in the central nervous system aimed at protecting and repairing damage to the brain in response to neural toxicity. Astrogliosis is generally accompanied by a rapid synthesis of GFAP (Eng et al. 2000); thus, an increase in GFAP is considered one of the first indicators of a deviation from normal physiology (Brahmachari et al. 2006).

Levels of GFAP in the sensorimotor cerebral cortex were significantly increased in gerbils exposed to 210 or 1,000 ppm of 1,1,1-trichloroethane, but not those exposed to 70 ppm. Levels of S-100 were not affected by treatment. Total protein levels were also unaffected by treatment. Brain weight was significantly reduced in gerbils exposed to 1,000 ppm.

Selection of the Point of Departure for the MRL: The lowest concentration administered, 70 ppm, is a NOAEL for neurotoxic effects. BMD modeling was not attempted as the data representing measurements of GFAP were not presented in a way that allowed for precise measurement of response.

Adjustment for Intermittent Exposure: As the gerbils in Rosengren et al. (1985) were continuously exposed for 3 months, there was no need to adjust for intermittent exposure. Therefore, the NOAEL of 70 ppm was not adjusted for exposure duration.

Uncertainty Factor: The NOAEL is divided by a total uncertainty factor of 100

- 10 for extrapolation from animals to humans
- 10 for human variability
  MRL = NOAEL ÷ uncertainty factors
  70 ÷ (10 x 10) = 0.7 ppm (4 mg/m^3^)

Other Additional Studies or Pertinent Information that Lend Support to this MRL: The choice of neurological effects as the critical end point of 1,1,1-trichloroethane toxicity is supported by both human and animal studies, which identified the nervous system as a particularly sensitive target of 1,1,1-trichloroethane toxicity following short-term exposures. For example, Gamberale and Hultengren (1973) observed psychophysiological test performance deficits in human subjects exposed to 250, 350, 450, and 550 ppm of 1,1,1-trichloroethane in consecutive 30-minute periods. Mackay et al. (1987) reported psychomotor deficits in human subjects exposed to 175 or 350 ppm of 1,1,1-trichloroethane for 3.5 hours. Increased motor activity was observed in mice exposed to 1,250 ppm of 1,1,1-trichloroethane for 30 minutes (Bowen and Balster 1996). A 4-hour exposure of mice to 2,064 ppm resulted in impaired swimming behavior (De Ceaurriz et al. 1983). Dow Chemical (1990) reported 1,1,1-trichloroethane-induced alterations in flash-evoked potential, SEP, and electroencephalogram in rats exposed to 1,000 ppm for 6 hours/day on 4 consecutive days. Mattsson et al. (1993) noted decreased forelimb grip strength in rats exposed to 2,000 ppm of 1,1,1-trichloroethane, 6 hours/day, 5 days/week for 13 weeks. Bowen and Balster (2006) observed a 166% increase in locomotor activity in mice exposed to 6,000 ppm of 1,1,1-trichloroethane, 30 minutes/day for 15 days.

Qualitative and quantitative analysis of GFAP has shown it to be a sensitive and specific indicator of gliosis, a hallmark feature of injury to the central nervous system (O'Callaghan and Sriram 2005). O’Callaghan and Sriram (2005) examined the effects of numerous known toxicants on GFAP and reported an increase in GFAP that is rapid, linked to the location of damage, and can occur at doses well below those associated with behavioral change. Although Rosengren et al. (1985) observed an increase in GFAP that was not accompanied by an increase in another marker of gliosis, S-100; there are no known or established relationships between changes in GFAP and changes in S-100 (O’Callaghan and Sriram 2005). This suggests that the increase in GFAP observed in Rosengren et al. (1985) is a valid indicator of neurotoxicity, even without additional neurotoxic or behavioral observations accompanying the change.

Agency Contacts (Chemical Managers): Carolyn Harper

## 1,1,1-Trichloroethane Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,1,1-Trichloroethane
CAS Numbers: | 71–55-6
Date: | March 2024
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL.

Rationale for Not Deriving an MRL: An MRL has not been derived for chronic-duration inhalation exposure to 1,1,1-trichloroethane because the database is insufficient. No adverse effects were observed in humans occupationally exposed to 1,1,1-trichloroethane at exposures up to 200 ppm (Kramer et al. 1978; Maroni et al. 1977). NOAELs and LOAELs for animals exposed chronically to inhaled 1,1,1-trichloroethane are summarized in Table A-3. The only noncancer endpoint observed in the chronic-duration inhalation database in animals was mild histopathological changes in the liver of rats exposed to 1,500 ppm 1,1,1-trichloroethane for 104 weeks (5 days/week, 6 hours/day), with a NOAEL of 500 ppm (Quast et al. 1988). However, no quantitative data or statistical analyses were reported regarding the incidence of hepatic lesions. Therefore, the Quast et al. (1988) study does not provide adequate information to serve as the principal study for derivation of the chronic-duration inhalation MRL. Other studies in rats and mice did not observe adverse effects at exposure levels up to 1,500 and 3,181 ppm, respectively (Ohnishi et al. 2013; Quast et al. 1988). The only other finding observed was hepatocellular adenoma in female mice at 201 ppm (Ohnishi et al. 2013); however, this effect cannot be used for derivation of the chronic-duration inhalation MRL because MRLs are based on noncancer endpoints. Therefore, a chronic-duration inhalation MRL for 1,1,1-trichloroethane was not derived.

Table A-3 Summary of NOAELs and LOAELs in Chronic-Duration Inhalation Studies on 1,1,1-Trichloroethane

Species | Duration/route | NOAEL (ppm) | LOAEL (ppm) | Effect | Reference
Hepatic effects
Rat F344 | 104 weeks 5 days/week 6 hours/day | 500 | 1,500 | Mild liver histopathology (accentuation of the normal hepatic lobular pattern, alteration in the size of the hepatocytes) | Quast et al. 1988
Rat F344 | 104 weeks 5 days/week 6 hours/day | 3,181 | | | Ohnishi et al. 2013
Mouse B6C3F1 | 104 weeks 5 days/week 6 hours/day | 1,500 | | | Quast et al. 1988
Mouse BDF1 | 104 weeks 5 days/week 6 hours/day | | 201 F (SLOAEL) | CEL: Hepatocellular adenoma | Ohnishi et al. 2013

Adjusted daily dose = i n t e r m i t t e n t d o s e × (e x p o s u r e h o u r s)/(24 h o u r s) × (e x p o s u r e d a y s)/(7 d a y s)

ADJ = adjusted; CEL = cancer effect level; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; SLOAEL: serious lowest-observed-adverse-effect level

Agency Contacts (Chemical Managers): Carolyn Harper

## 1,1,1-Trichloroethane Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,1,1-Trichloroethane
CAS Numbers: | 71-55-6
Date: | March 2024
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL due to insufficient information that could be used to identify sensitive endpoints.

Rationale for not deriving an MRL: An MRL has not been derived for acute-duration oral exposure (≤14 days) to 1,1,1-trichloroethane. The effects of acute-duration oral exposure of 1,1,1-trichloroethane have not been well studied. Six acute oral exposure studies were reported in four publications: two studies reporting LC_50_ data in mice and guinea pigs (Torkelson et al. 1958) and four studies that only evaluated a few toxicity endpoints (Bruckner et al. 2001; Platt and Cockrill 1969; Spencer et al. 1990). None of the available studies examined comprehensive toxicological endpoints. The lowest LOAEL was reported by Spencer et al. (1990) for neurological effects in female rats orally exposed to 705 mg/kg via gavage for 4 days; a NOAEL was not identified. Neurological effects were increased latency in flash-evoked potentials and a decrease in electroencephalogram at low power frequency. However, due to the lack of studies evaluating comprehensive effects, the acute oral database is considered inadequate for derivation of an acute-duration oral MRL.

Agency Contacts (Chemical Managers): Carolyn Harper

## 1,1,1-Trichloroethane Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,1,1-Trichloroethane
CAS Numbers: | 71–55-6
Date: | March 2024
Profile Status: | Final
Route: | Oral
Duration: | Intermediate
MRL: | 2 mg/kg/day
Critical Effect: | Reduction in body weight gain
Reference: | NTP 2000
Point of Departure: | BMDL_10_ of 208 mg/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 14
Species: | Mouse

MRL Summary: An intermediate-duration oral MRL of 2 mg/kg/day was derived for 1,1,1-trichloro-ethane based on a decrease in body weight gain in mice given diets containing encapsulated 1,1,1-trichloroethane (NTP 2000). The MRL is based on a BMDL_10_ of 208 mg/kg/day divided by a total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

Selection of the Critical Effect: A number of studies have evaluated the toxicity of 1,1,1-trichloroethane following intermediate-duration oral exposure; the potential endpoints examined include kidney and liver effects (Bruckner et al. 2001; NTP 2000), developmental and reproductive effects (Dow Chemical 1993; George et al. 1989; Lane et al. 1982; NTP 1988a, 1988b, 2000), and body weight effects (Bruckner et al. 2001; George et al. 1989; NTP 2000). The LOAELs for these studies range from 500 to 4,800 mg/kg/day. Table A-4 has a summary of relevant effect levels.

Table A-4 Summary of Relevant NOAEL and LOAEL Values Considered for Derivation of an Intermediate-Duration Oral MRL for 1,1,1-Trichloroethane

Species | Duration/route | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | BMDL_10_^a^ (mg/kg/day) | Effect | Reference
Hepatic effects
Rat Sprague-Dawley | 13 weeks 5 days/week (GO) | | 500 | | 144% increase in SDH activity | Bruckner et al. 2001
Rat F344/N | 13 weeks (F) | 2,500 F | 5,000 F | | 11% decrease in relative liver weight | NTP 2000
| | 2,400 M | 4,800 M | 4,621 | 12% decrease in relative liver weight
Renal effects
Rat F344/N | 13 weeks (F) | 600 M | 1,200 M | | 7/10 showed chronic inflammation | NTP 2000
Body weight
Mouse B6C3F1 | 13 weeks (F) | 1,340 F | 2,820 F | 380/2,192 (body weight gain/terminal body weight) | 22% decrease in body weight gain | NTP 2000
Mouse B6C3F1 | 13 weeks (F) | 1,340 F | 850 M | 208/678 (body weight gain/terminal body weight) | 18% decrease in body weight gain | NTP 2000
Rat F344/N | 13 weeks (F) | 2,400 M | 4,800 M | 3,844 (terminal body weight) | 10% decrease in final body weight | NTP 2000

a BMR is 10% relative deviation.

(F) = food; F = female(s); (GO) = gavage in oil vehicle; LOAEL = lowest-observed-adverse-effect level; M= male(s); NOAEL = no-observed-adverse-effect level; SDH = sorbitol dehydrogenase

The available data suggest that decreases in body weight gain are the most appropriate endpoint following intermediate-duration oral exposure. In female mice, decreased body weight gain was observed at 2,820 mg/kg/day, and in male mice, decreased body weight and body weight gain were observed at 850 mg/kg/day(NTP 2000). Although renal effects were seen at 1,200 mg/kg/day, chronic renal inflammation is a nonspecific effect, and hyaline degeneration in renal tubules occurred at 100% incidence at the LOAEL, which prevents any reasonable modeling of a dose-response relationship. There were also lower doses administered in the Bruckner et al. (2001) study that yielded changes in liver enzymes. Specifically, in Sprague-Dawley rats, increased SDH enzyme activity was observed following intermediate-duration exposure to 500 mg/kg/day via gavage. However, it may not be appropriate, in this case, to base an MRL on an effect level from a gavage study due to toxicokinetic considerations (e.g., possible bolus saturation of the detoxification/excretion mechanism). No other intermediate-duration oral study exhibited the hepatic effects observed in Bruckner et al. (2001).

Selection of the Principal Study: NTP (2000) conducted a study on effects of 1,1,1-trichloroethane oral exposure in rats and mice. There was a dose-related decrease in final mean body weight gain in male B6C3F1 mice at 5,000 ppm; mean body weight gain progressively decreased from 11.2 g at 5,000 ppm to 8.7 g at 80,000 ppm.

Summary of the Principal Study:

NTP. 2000. Technical report on the toxicity studies of 1,1,1-trichloroethane (CAS No. 71–55-6) administered in microcapsules in feed to F344/N rats and B6C3F1 mice. National Toxicology Program. (41) NIH 004402.

Groups of male and female B6C3F1 mice (10 per group) were fed diets containing 0 (untreated feed); 0 (microcapsule vehicle in feed); 5,000, 10,000, 20,000, 40,000, or 80,000 ppm of microencapsulated 1,1,1-trichloroethane (99% pure) 7 days/week for 13 weeks. Average daily doses calculated by the researchers were 850, 1,750, 3,500, 7,370, and 15,000 mg/kg in male mice and 1,340, 2,820, 5,600, 11,125, and 23,000 mg/kg in female mice. Clinical signs and body weights were recorded weekly. Food consumption was determined every 3–4 days. Water consumption was not reported. Vaginal cytology and sperm motility evaluations were performed on all mice in the vehicle control and the three highest dose groups of mice. At necropsy, all mice were subjected to gross pathological examinations, and the heart, lungs, thymus, liver, right kidney, and right testis were weighed. Mice in untreated and vehicle control and high-dose groups were subjected to complete histopathologic examinations.

There were no exposure-related deaths and no indications of treatment-related or histopathological effects. Food consumption was slightly increased in 1,1,1-trichloroethane-treated groups, relative to untreated and vehicle controls. However, final mean body weight and mean body weight gain of all treatment groups of male and female mice were lower than those of respective vehicle controls (see Table A-5). The final mean body weights in the 5,000, 10,000, 20,000, 40,000, and 80,000 ppm groups were 91, 91, 88, 90, and 85% (males) and 97, 93, 89, 88, and 84% (females) of the respective vehicle control means. As demonstrated in Table A-5, the treatment-related effects on final mean body weight and body weight gain reached the level of statistical significance in all treated groups of male mice and ≥20,000-ppm female mice, relative to vehicle controls. The 10,000-ppm group of female mice exhibited a significantly lower mean body weight gain, but not final mean body weight, relative to vehicle controls. NTP (2000) estimated the dose of 10,000 ppm (1,750 and 2,820 mg/kg/day in male and female mice, respectively) to represent a NOAEL. According to ATSDR policy, a treatment-related change in body weight ≥10% (relative to controls) may be considered to represent an adverse effect. Therefore, the 20,000 ppm (3,500 and 5,600 mg/kg/day in males and females, respectively) level is considered to represent a LOAEL for decreased mean terminal body weight (≥10% lower than control values).

Table A-5 Body Weight Data for Mice Administered 1,1,1-Trichloroethane in the Diet for 13 Weeks

Dose (mg/kg/day) | Final mean body weight (g) (±SE) | Percent of control^a^ (final body weight) | Mean weight gain (g) (±SE) | Percent of control^a^ (body weight gain)
Males
Vehicle control | 36.9±0.7 | | 13.7±0.5
850 | 33.6±0.7^b^ | 91 | 11.2±0.5^b^ | 82
1,750 | 33.7±0.6^b^ | 91 | 10.8±0.5^b^ | 79
3,500 | 32.7±0.5^b^ | 88 | 9.9±0.4^b^ | 72
7,370 | 33.1±0.5^b^ | 90 | 10.0±0.3^b^ | 73
15,000 | 31.3±0.4^b^ | 85 | 8.7±0.3^b^ | 64
Females
Vehicle control | 29.3±0.8 | | 11.2±0.8
1,340 | 28.4±0.6 | 97 | 9.6±0.7 | 86
2,820 | 27.2±0.8 | 93 | 8.7±0.6^b^ | 78
5,600 | 26.0±0.8^b^ | 89 | 7.5±0.7^b^ | 67
11,125 | 25.8±0.7^b^ | 88 | 7.2±0.6^b^ | 64
23,000 | 24.5±0.5^b^ | 84 | 6.2±0.5^b^ | 55

a Percent decrease relative to vehicle control.

b Significantly different (p≤0.01) from the vehicle control group.

SE = standard error

Source: NTP 2000

Selection of the Point of Departure for the MRL: BMD modeling was conducted to identify a point of departure (POD) using the body weight gain data in male mice given diets containing encapsulated 1,1,1-trichloroethane. Male mean body weight gain data from B6C3F1 mice, using the vehicle control as the control group, were selected for BMD analysis (Table A-5). This analysis used only terminal bodyweight of the male mice whereas the MRL previously derived for this duration of exposure was based on the terminal body weight of male and female mice in the study. The data were fit to all available continuous models in EPA’s Benchmark Dose Software (BMDS, version 3.2) using a benchmark response (BMR) of 10% relative deviation from the vehicle control, as this change in body weight is the minimal level of change generally considered to be biologically significant, according to the EPA BMD guidance (EPA 2012). Default setting for the application of restrictions were used. Adequate model fit was judged by four criteria: goodness-of-fit statistics (p-value >0.1), visual inspection of the dose-response curve, BMDL <10 times the lowest non-zero dose, and scaled residual at the data point (except the control) closest to the predefined BMR. Among all models providing adequate fit to the data, the BMDL from the model with the lowest Akaike’s Information Criterion (AIC) was chosen, since all BMDLs from the viable estimated models were within a 3-fold range. BMDS recommended the frequentist restricted Hill model with constant variance for body weight gain, and after verifying the model fit by the four criteria listed above, this model was selected as the basis for estimating this MRL. The only viable model output was this frequentist restricted Hill model, and as such, the BMD/BMDL values for MRL derivation are presented in Table A-6 and the fit of the selected model is presented in Figure A-1.

Table A-6 Selected Results from BMD Analysis of Body Weight Gain in Male Mice Given Diets Containing Encapsulated 1,1,1-Trichloroethane 7 Days/Week for 13 Weeks at Concentrations Resulting in Estimated Doses of 0 (Vehicle Controls), 850, 1,750, 3,500, 7,300, or 15,000 mg/kg/day (NTP 2000)

Model | BMD_10_ (mg/kg/day) | BMDL_10_ (mg/kg/day) | p-Value^a^ | AIC | Scaled residual^b^
Model | BMD_10_ (mg/kg/day) | BMDL_10_ (mg/kg/day) | p-Value^a^ | AIC | Dose above BMD | Dose below BMD
Exponential 2 (CV, normal) | 4,258.10 | 3,267.94 | <0.0001 | 230.72 | −2.13 | 3.51
Exponential 3 (CV, normal) | 4,258.06 | 3,267.95 | <0.0001 | 230.72 | −2.13 | 3.51
Exponential 4 (CV, normal) | 529.27 | 304.03 | 0.09 | 214.29 | −0.97 | 0.31
Exponential 5 (CV, normal) | 527.41 | 304.03 | 0.09 | 214.29 | −0.96 | 0.31
Hill (CV, normal) | 401.75 | 207.93 | 0.29 | 211.54 | 0.12 | 0.12
Polynomial Degree 5 (CV, normal) | 5,014.06 | 4,447.11 | <0.0001 | 232.31 | −2.20 | 3.69
Polynomial Degree 4 (CV, normal) | 5,014.06 | 4,010.10 | <0.0001 | 232.31 | −2.20 | 3.69
Polynomial Degree 3 (CV,- normal) | 5,014.06 | 4,010.14 | <0.0001 | 232.31 | −2.20 | 3.69
Polynomial Degree 2 (CV, normal) | 5,014.06 | 4,010.18 | <0.0001 | 232.31 | −2.20 | 3.69
Power (CV, normal) | 5,014.05 | 4,010.59 | <0.0001 | 232.31 | −2.20 | 3.69
Linear (CV, normal) | 5,014.06 | 4,010.56 | <0.0001 | 232.31 | −2.20 | 3.69

a Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

b Scaled residuals at doses immediately below and above the BMD; also the largest residual at any dose.

AIC = Akaike Information Criterion; BMD = benchmark dose (maximum likelihood estimate of the dose associated with the selected benchmark response); BMDL_10_ = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., 10 = dose associated with 10% relative deviation from control); CV = constant variance

Figure A-1 Fit of Hill Model to Data on Mean Body Weight Gain (in g) in Male Mice Given Diets Containing Encapsulated 1,1,1-Trichloroethane 7 Days/Week for 13 Weeks at Concentrations Resulting in Estimated Doses of 0 (Vehicle Controls), 850, 1,750, 3,500, 7,300, or 15,000 mg/kg/day

Uncertainty Factor: The BMDL_10_ of 208 mg/kg/day was divided by a total uncertainty factor of 100 (10 for human variability and 10 for extrapolation from animals to humans), resulting in an MRL of 2 mg/kg/day.

- 10 for extrapolation from animals to humans
- 10 for human variability
  MRL = BMDL_10_ ÷ uncertainty factors
  208 mg/kg/day ÷ (10 x 10) = 2.08 mg/kg/day ≈ 2 mg/kg/day

Other Additional Studies or Pertinent Information: Decreased body weight appears to be a sensitive effect in other intermediate- and chronic-duration studies by oral or inhalation routes of exposure, either in the absence of other signs of toxicity (Adams et al. 1950; Bruckner et al. 2001; Prendergast et al. 1967) or at doses causing minimal liver lesions (Calhoun et al. 1981; Quast et al. 1988).

Agency Contacts (Chemical Managers): Carolyn Harper, Ph.D.

## 1,1,1-Trichloroethane Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1,1,1-Trichloroethane
CAS Numbers: | 71-55-6
Date: | March 2024
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL due to lack of comprehensive toxicity evaluations.

Rationale for not deriving an MRL: An MRL has not been derived for chronic-duration oral exposure to 1,1,1-trichloroethane. The only noncancer effect following chronic-duration oral exposure to 1,1,1-trichloroethane was decreased body weight observed in two gavage studies (Maltoni et al. 1986; NCI 1977). Maltoni et al. (1986) identified a LOAEL of 500 mg/kg/day (only dose tested) for a 12% decrease in terminal body weight in female rats relative to control. At this same dose, leukemia was also observed. It is likely that decreased terminal body weight was secondary to leukemia rather than a primary effect of 1,1,1-trichloroethane on body weight. This uncertainty precludes body weight effect to derive the MRL. NCI (1977) reported an 18% decrease terminal body weight at 2,807 mg/kg/day (lowest dose tested) in male and female mice. In this study, 22/50 females died and 28/50 males died at the 2,807 mg/kg/day dose. Therefore, a LOAEL of 2,807 mg/kg/day cannot be used to derive a chronic-duration oral MRL.

Agency Contacts (Chemical Managers): Carolyn Harper, Ph.D.