# Consensus Panel

- Richard K. Ries, M.D., Chair
- Director
- Inpatient Psychiatry and Dual Disorder Programs
- Harborview Medical Center
- Seattle, Washington

Facilitators
- Marcelino Cruces, L.C.S.W.
- Administrative Coordinator
- Andromeda Transcultural Mental Health Center
- Substance Abuse Treatment Division
- Washington, D.C.
- Mary Katherine Evans, C.A.D.C., N.C.A.C. II
- Program Director
- Evans and Sullivan
- Beaverton, Oregon
- James Fine, M.D.
- Director
- Addictive Disease Hospital at Kings County Hospital Center
- Clinical Associate Professor
- Department of Psychiatry
- State University of New York
- Health Service Center at Brooklyn
- Brooklyn, New York
- Bonnie Schorske, M.A.
- Coordinator
- Special Populations
- New Jersey Division of Mental Health and Hospitals
- Trenton, New Jersey

Workgroup Members
- Stephen J. Bartels, M.D.
- Medical Director
- West Central Services, Inc.
- Research Associate
- New Hampshire-Dartmouth Psychiatric Research Center
- Lebanon, New Hampshire
- Dolores Burant, M.D.
- Program and Medical Director
- University Outpatient Recovery Service
- Madison, Wisconsin
- Agnes Furey, L.P.N., C.A.P.
- Primary Care Coordinator
- Florida Alcohol and Drug Abuse Program
- Department of Health and Rehabilitation Services
- Tallahassee, Florida
- Malcolm Heard, M.S.
- Director
- Division on Alcoholism and Drug Abuse
- Nebraska Department of Public Institutions
- Lincoln, Nebraska
- Norman Miller, M.D.
- Associate Professor of Psychiatry
- Chief, Addiction Programs
- Department of Psychiatry
- University of Illinois at Chicago
- Chicago, Illinois
- Ernest Quimby, Ph.D.
- Assistant Graduate Professor
- Howard University
- Department of Sociology and Anthropology
- Washington, D.C.
- Henry Jay Richards, Ph.D.
- Associate Director for Behavioral Sciences
- Patuxent Institution
- Jessup, Maryland
- Candace Shelton, M.S., C. A.C.
- Clinical Director
- Pascua Yaqui Adult Treatment Home
- Tucson, Arizona
- Virginia Stiepock, A.C.S.W, R.N., C.S.
- Assistant Center Director
- Clinical Director
- Northern Rhode Island Community Mental Health Center
- Woonsocket, Rhode Island
- Mathias Stricherz, Ed.D., C.D.C. III
- Director
- Student Counseling Center
- University of South Dakota
- Vermillion, South Dakota
- Patricia M. Weisser
- National Association of Psychiatric Survivors
- Sioux Falls, South Dakota
- Joan Ellen Zweben, Ph.D.
- Executive Director
- The East Bay Community Recovery Project
- The 14th Street Clinic and Medical Group
- Berkeley, California