# Appendix D—Field Reviewers

- Arthur I. Alterman, Ph.D.
- Scientific Director
- Center for Studies of Addiction
- University of Pennsylvania School of Medicine
- Philadelphia, Pennsylvania

- Robert Anderson
- Director, Criminal Justice
- National Association of State Alcohol and Drug Abuse Directors

- Gloria J. Baciewicz, M.D.
- Director
- Alcoholism and Drug Dependency Program
- University of Rochester Medical Center
- Rochester, New York

- Stephen J. Bartels, M.D.
- Medical Director
- West Central Services, Inc.
- Research Associate
- N.H. Dartmouth Psychiatric Research Center
- Lebanon, New Hampshire

- Richard J. Bast
- Public Health Advisor
- Center for Substance Abuse Treatment

- Joseph J. Bevilaqua, Ph.D.
- Director
- South Carolina Department of Mental Health

- Dolores M. Burant, M.D.
- Program Director and Medical Director
- University Outpatient Recovery Services
- Madison, Wisconsin

- Ricardo Castaneda, M.D.
- Director
- Inpatient Psychiatry at Bellevue Hospital
- New York Medical Center

- Nancy C. Carter
- Director
- Special Division for Alcohol and Drug Abuse Services
- South Carolina Department of Mental Health

- Maureen Connelly, Ph.D.
- Professor
- Department of Sociology and Social Work
- Frostburg State University
- Frostburg, Maryland

- Marcelino Cruces, L.I.C.S.W.
- Administrative Coordinator
- Andromeda Transcultural Mental Health Center
- Substance Abuse Treatment Division
- Washington, D.C.

- Dorynne Czechowicz, M.D.
- Associate Director for Medical and Professional Affairs
- Division of Clinical Research
- National Institute on Drug Abuse

- Robert E. Drake, M.D., Ph.D.
- Professor/Director
- N.H.-Dartmouth Psychiatric Research Center
- Dartmouth Medical School
- Lebanon, New Hampshire

- Mary Katherine Evans, C.A.D.C., N.C.A.C. II
- Treatment Coordinator
- Evans and Sullivan
- Beaverton, Oregon

- Walter L. Faggett, M.D.
- Pediatrics/Health Care Consultant
- Capitol Area Health Services
- National Medical Association

- Denis Ferguson, M.A., C.S.A.D.C.
- Program Manager
- Substance Abuse Services
- DuPage County Health Department
- Wheaton, Illinois

- James Fine, M.D.
- Director
- Addictive Disease Hospital at Kings County Hospital Center
- Clinical Associate Professor
- Department of Psychiatry
- State University of New York
- Health Service Center at Brooklyn
- Brooklyn, New York

- Agnes Furey, L.P.N., C.A.P.
- Primary Care Coordinator
- Florida Drug and Alcohol Abuse Program
- Department of Health and Rehabilitation Services
- Tallahassee, Florida

- Harry W. Haverkos, M.D.
- Acting Director
- Division of Clinical Research
- National Institute on Drug Abuse

- Elizabeth A. Irvin, M.S.W.
- Director of Service Integration
- Department of Mental Health
- Commonwealth of Massachusetts

- Edward K. Katz, M.D., M.P.H.
- Mind Science
- Consultation for Problems in Thinking and Feeling
- Stow, Ohio

- Ruth H. Carlsen Kahn, D.N.Sc., R.N.
- Special Projects Section
- Division of Medicine
- Bureau of Health Professions
- Health Resources and Services Administration

- George Kolodner, M.D.
- Kolmac Clinic
- Silver Spring, Maryland

- Susan Krupnick, R.N., M.S.N., C.A.R.N., C.S.
- Psychiatric Consultation Liaison Nurse
- Department of Psychiatric Nursing
- Hospital of the University of Pennsylvania
- Fox Chase Manor, Pennsylvania

- Robert M. Lichtman, Ph.D., C.A.C.
- Associate Psychologist/Program Coordinator
- Richmond Hill Outpatient Division
- Creedmoor Psychiatric Center
- Richmond Hill, New York

- Herbert J. McBride
- President and Medical Director
- Re-Enter, Inc.
- Philadelphia, Pennsylvania

- Catherine Devaney McKay, M.D.
- Chief Executive Officer
- Connections Community Support Programs, Inc.
- Wilmington, Delaware

- Norman S. Miller, M.D.
- Associate Professor of Psychiatry
- Department of Psychiatry
- University of Illinois at Chicago

- Thomas Neslund
- Executive Director
- International Commission for the Prevention of Alcoholism and Drug Dependency
- Silver Spring, Maryland

- John Nielsen, L.P.C., C.C.D.C., M.S.S.
- Alcohol and Other Drugs Counselor
- Threshold Youth Services
- Sioux Falls, South Dakota

- Robert E. Nikkel, M.S.W.
- Coordinator
- Adult Program Services Team
- Mental Health and Development Services Division
- Office of Mental Health Services
- State of Oregon

- Fred C. Osher, M.D.
- Acting Director for Demonstration Programs
- Center for Mental Health Services

- William C. Panepinto, A.C. S.W.
- Assistant Director
- Homelessness/Housing Unit
- New York State Office of Alcoholism and Substance Abuse Services

- T. Allan Pearson, M.S.W.
- Mental Health, Alcohol, and Other Drug Abuse Counselor
- Ozaukae County Department of Community Programs
- Port Washington, Wisconsin

- Walter E. Penk, Ph.D.
- Chief
- Psychology Services
- Edit Nourse Rogers Memorial Veterans Hospital Bedford, Massachusetts

- Harold I. Perl, Ph.D.
- Public Health Analyst
- Homeless Demonstration and Evaluation Branch
- National Institute on Alcohol Abuse and Alcoholism

- Ernest Quimby, Ph.D.
- Assistant Graduate Professor
- Department of Sociology and Anthropology
- Howard University
- Washington, D.C.

- Kathleen Reynolds, M.S.W., A.C.S.W.
- Associate Coordinator
- Livingston/Washtenaw Substance Abuse Coordinating Agency
- Washtenaw Community Mental Health
- Ypsilanti, Michigan

- Henry Jay Richards, Ph.D.
- Associate Director for Behavioral Sciences
- Patuxent Institution
- Jessup, Maryland

- Richard K. Ries, M.D.
- Director of Inpatient Psychiatry and Dual Disorder Programs
- Harborview Medical Center
- Seattle, Washington

- Bruce J. Rounsaville, M.D.
- Associate Professor of Psychiatry
- Division of Substance Abuse
- Yale School of Medicine
- New Haven, Connecticut

- Harry Schnibbe
- Executive Director
- National Association of State Mental Health Program Directors

- Bonnie Schorske, M.A.
- Coordinator
- Special Populations
- New Jersey Division of Mental Health and Hospitals

- Candace Shelton, M.S., C.A.C.
- Clinical Director
- Pascua Yaqui Adult Treatment Home
- Tucson, Arizona

- Elizabeth C. Shifflette, Ed.D.
- Staff Development and Training Coordinator
- South Carolina Commission on Alcohol and Drug Abuse

- Virginia Stiepock, R.N., A.C.S.W., C.S.
- Assistant Center Director/Clinical Director
- Northern Rhode Island Community Mental Health Center, Inc.
- Woonsocket, Rhode Island

- Mathias E. Stricherz, Ed.D., C.D.C. III
- Director
- Student Counseling Center
- University of South Dakota
- Vermillion, South Dakota

- J. Michael Sullivan, Ph.D.
- Clinical Director
- Evans and Sullivan
- Beaverton, Oregon

- Johnie L. Underwood, B.S., C.S.W.
- Assistant Deputy Director
- Division of Mental Health and Addictions
- Indiana Family Social Services Administration

- Mark C. Wallen, M.D.
- Medical/Clinical Director
- Livengrin Foundation, Inc.
- Bensalem, Pennsylvania

- Linda M. Washington, M.S.N., R.N., C.S.-P.
- Psychiatric Nurse Clinical Specialist
- Outpatient Addictions Services
- Montgomery County Department of Addictions, Victims, and Mental Health Services
- Rockville, Maryland

- Patricia M. Weisser
- National Association of Psychiatric Survivors
- Sioux Falls, South Dakota

- Sonya Cornell Yarmat, M.A.
- Consultant
- Division of Alcohol and Drug Abuse Services
- Department of Social Rehabilitation
- Topeka, Kansas

- Doug Ziedonis, M.D.
- Assistant Professor
- Department of Psychiatry
- Medical Director, Substance Abuse Treatment Unit
- Outpatient Services
- Yale University
- New Haven, Connecticut

- Joan Ellen Zweben, Ph.D.
- Executive Director
- East Bay Community Recovery Project
- 14th Street Clinic and Medical Group
- Berkeley, California