# Appendix C—Federal Resource Panel

- John J. Ambre, M.D., Ph.D.
- American Medical Association

- Robert Anderson
- Director
- Criminal Justice Service
- National Association of State Alcohol and Drug Abuse Directors

- Richard J. Bast
- Public Health Advisor
- Quality Assurance and Evaluation Branch
- Division of State Programs
- Center for Substance Abuse Treatment

- Sandra M. Clunies, M.S., N.C.A.D.C.
- President, Maryland Addiction Counselor Certification Board

- Dorynne Czechowicz, M.D.
- Associate Director
- Medical and Professional Affairs
- Division of Clinical Research
- National Institute on Drug Abuse

- Walter L. Faggett, M.D.
- National Medical Association

- Rita Goodman, M.S., R.N.C.
- Nurse Consultant
- Division of Primary Care Services
- Health Resources and Services Administration

- John Gregrich
- Policy Analyst
- Office for National Drug Control Policy
- Executive Office for the President

- Claudia Hart
- American Psychiatric Association

- Ruth H. Carlsen Kahn, D.N.Sc.
- Special Projects Section
- Division of Medicine
- Bureau of Health Professions
- Health Resources and Services Administration

- Saul M. Levin, M.D.
- Director
- Office of Health Care Linkage
- Center for Substance Abuse Treatment

- Cherry Lowman, Ph.D.
- Health Scientist Administrator
- Treatment Research Branch
- Division of Clinical and Prevention Research
- National Institute on Alcohol Abuse and Alcoholism

- Anna Marsh, Ph.D.
- Associate Director for Evaluation
- Office of Applied Studies
- Center for Substance Abuse Treatment

- Fred C. Osher, M.D.
- Deputy Director
- Office of Programs for the Homeless Mentally Ill
- National Institute of Mental Health

- Deborah Parham, Ph.D., R.N.
- Chief
- Special Initiatives
- Policy and Evaluation Branch
- Bureau of Primary Health Care
- Health Resources and Services Administration

- Kay Pearson, R.Ph., M.P.H.
- Senior Health Policy Analyst
- Agency for Health Care Policy and Research
- Public Health Service

- Bert Pepper, M.D.
- The Information Exchange
- New City, New York

- Richard K. Ries, M.D. (Chair)
- Director of Inpatient Psychiatry and Dual Disorder Programs
- Harborview Medical Center
- Seattle, Washington

- Harry Schnibbe
- Executive Director
- National Association of State Mental Health Program Directors

- Sarah Stanley, M.S., R.N., C.N.A, C.S.
- American Nurses Association

- Patricia M. Weisser
- National Association of Psychiatric Survivors