# Appendix A -- Bibliography

Africa, B., and Schwartz, S.R. Schizophrenic disorders. In: Goldman, H.H., ed. Review of General Psychiatry, Third Edition. Norwalk, Connecticut: Appleton & Lange, 1992. pp. 226-241.
American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders, Third Edition, Revised. Washington, D.C.: American Psychiatric Association, 1987.
American Psychiatric Association. DSM-IV Draft Criteria, 3/1/93. Washington, D.C.: American Psychiatric Association, 1993.
Anthenelli, R.M., and Schuckit, M.A. Affective and anxiety disorders and alcohol and drug dependence: diagnosis and treatment. Journal of Addictive Diseases. 1993;12(3):73-87. [pmid: 8251547].
Baker, F. Coordination of alcohol, drug abuse, and mental health services. Technical Assistance Publication Series Number 4. Washington, D.C.: Office for Treatment Improvement, Alcohol, Drug Abuse, and Mental Health Administration. 1991.
Balster, R.L. Abuse potential of buspirone and related drugs. Journal of Clinical Psychopharmacology. 1990;10(3, Suppl.):31S-37S. [pmid: 1973938].
Beck, A.T., and Ward, J. Beck Depression Inventory. In: Beck A.T., ed., Depression: Causes and Treatment. Philadelphia: University of Pennsylvania Press, 1972.
Bernadt, M.W., and Murray, R.M. Psychiatric disorder, drinking and alcoholism: what are the links?. British Journal of Psychiatry. 1986;148:393-400. [pmid: 3730705].
Blume, S.B. Dual diagnosis: Psychoactive substance dependence and the personality disorders. Journal of Psychoactive Drugs. 1989;21(2):139-144. [pmid: 2668480].
Brown, R.L. Identification and office management of alcohol and drug disorders. In: Fleming, M.F., and Barry, K.L., eds. Addictive Disorders. St. Louis: Mosby Yearbook, 1992.
Brown, V.B., Ridgely, M.S., Pepper, B., Levine, I.R., and Ryglewicz, H. The dual crisis: Mental illness and substance abuse, present and future directions. American Psychologist. 1989;44(3):565-569. [pmid: 2648909].
Bryant, K.J., Rounsaville, B., Spitzer, R.L., and Williams, J.B. Reliability of dual diagnosis, substance dependence and psychiatric disorders. Journal of Nervous and Mental Disease. 1992;180(4):251-257. [pmid: 1556565].
Burns, D.D. The Feeling Good Handbook. New York: Penguin Books. 1989.
Carmen, E., and Brady, S.M. AIDS risk and prevention for the chronic mentally ill. Hospital and Community Psychiatry. 1990;41(6):652-657. [pmid: 2361669].
Castaneda, Casteneda, R., Galanter, M., and Franco, H. Self-medication among addicts with primary psychiatric disorders. Comprehensive Psychiatry. 1989;30(1):80-83. [pmid: 2784368].
Castaneda, R., Galanter, M., Lifshutz, H., and Franco, H. Effects of drugs of abuse on psychiatric symptoms among hospitalized schizophrenics. American Journal of Drug and Alcohol Abuse. 1991;17(3):313-320. [pmid: 1928025].
Caton, C.L., Gralnick, A., Bender, S., and Simon, R. Young chronic patients and substance abuse. Hospital and Community Psychiatry. 1989;40(10):1037-1040. [pmid: 2807204].
Ciraulo, D.A., Barnhill, J.G., Ciraulo, A.M., Greenblatt, D.J., and Shader, R.I. Parental alcoholism as a risk factor in benzodiazepine abuse: A pilot study. American Journal of Psychiatry. 1989;146:1333-1335. [pmid: 2782481].
Ciraulo, D. A., Barnhill, J.G., Greenblatt, D.J., Shader, R.I., Ciraulo, A.M., Tarmey, M.F., Molloy, M.A., and Foti, M.E. Abuse liability and clinical pharmacokinetics of alprazolam in alcoholic men. Journal of Clinical Psychiatry. 1988;49:333-337. [pmid: 3417618].
Clark, H.W., and Zweben, J.E. Legal vulnerabilities in the treatment of chemically dependent dual diagnosis patients. Journal of Psychoactive Drugs. 1989;21(2):251-257. [pmid: 2569509].
Davis, G.C., and Goldman, B. Somatic therapies. In: Goldman, H.H., ed. Review of General Psychiatry, Third Edition. Norwalk, Connecticut: Appleton & Lange, 1992. pp. 370-390.
Dixon, L., Haas, G., Weiden, P., Sweeney, J., and Frances, A. Acute effects of drug abuse in schizophrenic patients: clinical observations and patients' self-reports. Schizophrenia Bulletin. 1990;16(1):69-79. [pmid: 2185536].
Domisse, Dommisse, C.S., and Hayes, P.E. Current concepts in clinical therapeutics: anxiety disorders, Part 2. Clinical Pharmacy. 1987;6:196-215. [pmid: 2889558].
Drake, R.E., Osher, F.C., and Wallach, M.A. Homelessness and dual diagnosis. American Psychologist. 1991;46(11):1149-1158. [pmid: 1772152].
Evans, K., and Sullivan, J.M. Dual Diagnosis: Counseling the Mentally Ill Substance Abuser. New York: Guilford Press, 1990.
Evans, K., and Sullivan, J.M. Step Study Counseling With the Dual Disordered Client. Center City, Minnesota: Hazelden Educational Materials. 1990.
Fischer, P.J., and Breakey, W.R. The epidemiology of alcohol, drug, and mental disorders among homeless persons. American Psychologist. 1991;46(11):1115-1126. [pmid: 1772149].
Gold, M.S. The Good News About Depression. New York: Villard Books. 1987.
Gold, M.S. The Good News About Drugs and Alcohol. New York: Villard Books. 1990.
Gold, M.S. The Good News About Panic, Anxiety, and Phobias. New York: Villard Books. 1989.
Goldman, M.S. Neuropsychological recovery in alcoholics: endogenous and exogenous processes. Alcoholism: Clinical and Experimental Research. 1986;10(2):136-144.
Gordon, S.M., Kennedy, B.P., and McPeake, J.D. Neuropsychologically impaired alcoholics: assessment, treatment considerations, and rehabilitation. Journal of Substance Abuse Treatment. 1988;5:99-104. [pmid: 3392758].
Gorelick, D.A. Serotonin uptake blockers and the treatment of alcoholism. In: Galanter, M., ed. Recent Developments in Alcoholism. New York: Plenum Press, 1989. pp. 267-281.
El-Guebaly, N. Substance abuse and mental disorders: the dual diagnoses concept. Canadian Journal of Psychiatry. 1990;35:261-267.
Hasin, D.S., Endicott, J., and Keller, M.B. Alcohol problems in psychiatric patients: 5-year course. Comprehensive Psychiatry. 1991;32(4):303-316. [pmid: 1935019].
Hedlund, J.L., and Vieweg, M.S. The Michigan Alcoholism Screening Test (MAST). Journal of Operational Psychiatry. 1984;15:55-64.
Hendrickson, E.L. Treating the dually diagnosed (mental disorder/substance use) client. Tie Lines. 1988;4(4):1-6.
Jensen, K.L. Family issues in treating the "dually diagnosed" client. Tie Lines. 1990;7:6-8.
Kofoed, L., Kania, J., Walsh, T., and Atkinson, R.M. Outpatient treatment of patients with substance abuse and coexisting psychiatric disorders. American Journal of Psychiatry. 1986;143(7):867-872. [pmid: 3087222].
Kofoed, L., and Keys, A. Using group therapy to persuade dual-diagnosis patients to seek substance abuse treatment. Hospital and Community Psychiatry. 1988;39(11):1209-1211. [pmid: 3224959].
Kranzler, H.R., and Liebowitz, N.R. Anxiety and depression in substance abuse: clinical implications. Medical Clinics of North America. 1988;72(4):867-885. [pmid: 3287042].
Lader, M. Beta-Adrenoceptor antagonists in neuropsychiatry: an update. Journal of Clinical Psychiatry. 1988;49:213-223. [pmid: 2897959].
Landry, M.J., Smith, D.E., McDuff, D.R., and Baughman, O.L., 3rd. Anxiety and substance use disorders: the treatment of high-risk patients. Journal of the American Board of Family Practice. 1991;4:447-456.
Landry, M.J., Smith, D.E., and Steinberg, J.R. Anxiety, depression, and substance use disorders: diagnosis, treatment, and prescribing practices. Journal of Psychoactive Drugs 23(4):397-416, 1991a.
Lehman, A.F., Myers, C.P., and Corty, E. Assessment and classification of patients with psychiatric and substance abuse syndromes. Hospital and Community Psychiatry. 1989;40(10):1019-1030. [pmid: 2680876].
Mayfield, D., McLeod, G., and Hall, P. The CAGE questionnaire: validation of a new alcoholism screening instrument. American Journal of Psychiatry. 1974;131(10):1121-1123. [pmid: 4416585].
McLellan, A.T. Predicting response to alcohol and drug abuse treatments: the role of psychiatric severity. Archives of General Psychiatry. 1983;40:620-625. [pmid: 6847331].
McLellan, A.T., Luborsky, L., Woody, G.E., and O'Brien, C.P. An improved diagnostic evaluation instrument for substance abuse patients: the Addiction Severity Index. 1980;168:26-33.
Meek, P.S., Clark, H.W., and Solana, V.L. Neurocognitive impairment: the unrecognized component of dual diagnosis in substance abuse treatment. Journal of Psychoactive Drugs. 1989;21(2):153-160. [pmid: 2760756].
Meltzer, E.O. Performance effects of antihistamines. Journal of Allergy and Clinical Immunology. 1990;86(4, Part 2):613-619. [pmid: 2229823].
Meyer, R.E. How to understand the relationship between psychopathology and addictive disorders: another example of the chicken and the egg. In: Meyer, R.E., ed. Psychopathology and Addictive Disorders. New York: Guilford Press, 1986.
Meyer, R.E. Prospects for a rational pharmacotherapy of alcoholism. Journal of Clinical Psychiatry 50(11):403-412, 1989.
MICA Advisory Committee, State of New Jersey. Glossary of terms common in MICA treatment. Trenton, New Jersey: State of New Jersey, 1992.
Miller, N.S., and Ries, R.K. Drug and alcohol dependence and psychiatric populations: the need for diagnosis, intervention, and training. Comprehensive Psychiatry. 1991;32(3):268-276. [pmid: 1884607].
Minkoff, K. An integrated treatment model for dual diagnosis of psychosis and addiction. Hospital and Community Psychiatry. 1989;40(10):1031-1036. [pmid: 2807203].
Minkoff, K., and Drake, R.E., eds. Dual Diagnosis of Major Mental Illness and Substance Disorder. San Francisco: Jossey-Bass, Inc., 1991.
Mooney, A.J., Eisenberg, A, and Eisenberg, H. The Recovery Book. New York: Workman Publishers. 1992.
Morris, S.K., and Schinke, S.P. Treatment needs and services for mothers with a dual diagnosis: substance abuse and mental illness. In: Chaneles, S., and Pallone, N.J., eds. Clinical Treatment of the Criminal Offender in Outpatient Mental Health Settings: New and Emerging Perspectives. New York: Haworth Press, 1990. pp. 65-84.
Nace, E.P., Davis, C.W., and Gaspari, J.P. Axis II comorbidity in substance abusers. American Journal of Psychiatry. 1991;148(1):118-120. [pmid: 1984695].
Nace, E.P., Saxon, J.J., and Shore, N. Borderline personality disorder and alcoholism treatment: a one-year follow-up study. Journal of Studies on Alcohol. 1986;47(3):196-200. [pmid: 3724153].
Osher, F.C., and Kofoed, L.L. Treatment of patients with psychiatric and psychoactive substance use disorders. Hospital and Community Psychiatry. 1989;40(10):1025-1030. [pmid: 2807202].
Padgett, D., Struening, E.L., and Andrews, H. Factors affecting the use of medical, mental health, alcohol, and drug treatment services by homeless adults. Medical Care. 1990;28(9):805-821. [pmid: 2402175].
Penick, E.C., Powell, B.J., Liskow, B.I., Jackson, J.O., and Nickel, E.J. The stability of coexisting psychiatric syndromes in alcoholic men after one year. Journal of Studies on Alcohol. 1988;49:395-405. [pmid: 3270510].
Pepper, B., and Ryglewicz, H. The young adult chronic patient and substance abuse. Tie Lines. 1984;1(2):1-5.
Pepper, B., and Ryglewicz, H. Dual-disorder treatment. Maine Dual Disorders Monographs, Volume 3. Maine Department of Mental Health and Mental Retardation. 1989.
Petracca, A., Nisita, C., McNair, D., Melis, G., Guerani, G., and Cassano, G.B. Treatment of generalized anxiety disorder: preliminary clinical experience with buspirone. Journal of Clinical Psychiatry. 1990;51(9, Suppl.):31-39. [pmid: 2211564].
Quinnet, P. When Self-Help Fails. New York: Crossroads. 1991.
Regier, D.A., Boyd, J.H., Burke, J.D., Rae, D. S., Myers, J.K., Kramer, M., Robins, L.N., George, L.K., Karno, M., and Locke, B.Z. One-month prevalence of mental disorders in the United States: based on five Epidemiologic Catchment Area sites. Archives of General Psychiatry. 1988;45:977-986. [pmid: 3263101].
Regier, D.A., Farmer, M.E., Rae, D.S., Locke, B.Z., Keith, S.J., Judd, L.L., and Goodwin, F.K. Comorbidity of mental disorders with alcohol and other drug abuse: results from the Epidemiologic Catchment Area (ECA) study. Journal of the American Medical Association. 1990;264(19):2511-2518. [pmid: 2232018].
Regier, D.A., Narrow, W.E., and Rae, D.S. The epidemiology of anxiety disorders: the Epidemiologic Catchment Area (ECA) experience. Journal of Psychiatric Research 24(Suppl. 2):3-14, 1990a.
Reid, W.H. The Treatment of Psychiatric Disorders. New York: Brunner/Mazel. 1989.
Reus, V.I. Mood disorders. In: Goldman, H.H., ed. Review of General Psychiatry, Third Edition. Norwalk, Connecticut: Appleton & Lange, 1992. pp. 226-241.
Rickels, K., Weisman, K., Norstad, N., Singer, M., Stoltz, D., Brown, A., and Danton, J. Buspirone and diazepam in anxiety: a controlled study. Journal of Clinical Psychiatry. 1982;43(12, Sec. 20):81-86. [pmid: 6130078].
Ries, R. Clinical treatment matching models for dually diagnosed patients. Psychiatric Clinics of North America. 1993;16(1):167-175. [pmid: 8456042].
Ries, R.K. The dually diagnosed patient with psychotic symptoms. Journal of Addictive Diseases. 1993a;12(3):103-122. [pmid: 8251538].
Ries, R.K., and Ellingson, T. A pilot assessment at one month of 17 dual diagnosis patients. Hospital and Community Psychiatry. 1990;41(11):1230-1233. [pmid: 2249802].
Robins, E., Helzer, J.E., and Przybeck, T.R. Alcohol disorders in the community: a report from the Epidemiologic Catchment Area study. In: Rose, R., and Barret J., eds. Alcoholism: Origins and Outcome. New York: Raven Press, 1988. pp. 15-28.
Rosenheck, R., Massari, L., Astrachan, B., and Suchinsky, R. Mentally ill chemical abusers discharged from VA inpatient treatment: 1976-1988. Psychiatric Quarterly. 1990;61(4):237-249. [pmid: 2103008].
Ross, H.E., Glaser, F.B., and Germanson, T. The prevalence of psychiatric disorders in patients with alcohol and other drug problems. Archives of General Psychiatry. 1988;45:1023-1031. [pmid: 3263100].
Rounsaville, B.J., Anton, S.F., Carroll, K., Budde, D., Prusoff, B.A., and Gawin, F. Psychiatric diagnoses of treatment-seeking cocaine abusers. Archives of General Psychiatry. 1991;48:43-51. [pmid: 1984761].
Ryglewicz, H. Psychoeducation: A wave of the present. Tie Lines. 1989;6(2):1-5.
Salloum, I.M., Moss, H.B., and Daley, D.C. Substance abuse and schizophrenia: impediments to optimal care. American Journal of Alcohol Abuse. 1991;17(3):321-336.
Salzman, C. Treatment with antianxiety agents. In: Treatments of Psychiatric Disorders. Washington, D.C.: American Psychiatric Association, 1989. pp. 2036-2052.
Schorske, B., and Bedard, K. One State's role in building a continuum of care for severe mental illness and chemical dependency. Community Support Network News. 1989;6(2).
Schuckit, M.A. Genetic and clinical implications of alcoholism and affective disorder. American Journal of Psychiatry. 1986;143(2):140-147. [pmid: 3511739].
Spitzer, R.L., Williams, J.B.W., Gibbon, M., and First, M. B. Structured Clinical Interview for DSM-III-R. Washington, D.C.: American Psychiatric Press, 1990.
Strand, M., Hetta, J., Rosen, A., Sorensen, S., Malmstrom, R., Fabian, C., Marits, K., Vetterskog, K., Liljestrand, A.-G., and Hegen, C. A double-blind, controlled trial in primary care patients with generalized anxiety: a comparison between buspirone and oxazepam. Journal of Clinical Psychiatry. 1990;51(9, Suppl.):40-45. [pmid: 2211567].
Stoffelmayr, B.E., Benishek, L.A., Humphreys, K., Lee, J.A., and Mavis, B.E. Substance abuse prognosis with an additional psychiatric diagnosis: understanding the relationship. Journal of Psychoactive Drugs. 1989;21(2):145-152. [pmid: 2760755].
Teague, G., Mercer-McFadden, C., and Drake, R.E. Dual diagnosis and continuity of care: New Hampshire's integrated initiatives for dual diagnosis patients. Tie Lines. 1989;6(1):1-3.
Thacker, W., and Tremaine, L. Systems issues in serving the mentally ill substance abuser: Virginia's experience. Hospital and Community Psychiatry. 1989;40(10):1046-1049. [pmid: 2807206].
Torrey, E.F. Surviving Schizophrenia: A Family Manual. New York: Harper & Row. 1983.
Trevor, A.J., and Way, W.L. Drugs used for anxiety states and sleep problems. In: Goldman, H.H., ed. Review of General Psychiatry, Second Edition. Norwalk, Connecticut: Appleton & Lange, 1989.
Turner, W.M., and Tsuang, M.T. Impact of substance abuse on the course and outcome of schizophrenia. Schizophrenia Bulletin. 1990;16(1):87-95. [pmid: 2185537].
Uhde, T.W., Stein, M.B., Vittone, B.J., Siever, L.J., Boulenger, J.P., Klein, E., and Mellman, T. A. Behavioral and physiologic effects of short-term and long-term administration of clonidine in panic disorders. Archives of General Psychiatry. 1989;46(2):170-177. [pmid: 2643934].
Wallen, M., and Weiner, H. The dually diagnosed patient in an inpatient chemical dependency treatment program. Alcoholism Treatment Quarterly. 1988;5(1/2):197-218.
Weiss, D.S., and Billings, J.H. Behavioral medicine techniques. In: Goldman, H.H., ed. Review of General Psychiatry, Second Edition. Norwalk, Connecticut: Appleton & Lange, 1989. pp. 574-579.
Weiss, R.D., M.L. Griffin, and Mirin, S.M. Drug abuse as self-medication for depression: an empirical study. American Journal of Drug and Alcohol Abuse. 1992;18:121-129. [pmid: 1562010].
Weissman, M.M. The epidemiology of anxiety disorders: rates, risks and familial patterns. Journal of Psychiatric Research. 1988;22(Suppl. 1):99-114. [pmid: 3050062].
Winter, A.S. When Self-Help Isn't Enough. Washington, D.C.: Psychiatric Institutes of America Press, 1990.
Wolfe, H.L., and Sorensen, J.L. Dual diagnosis patients in the urban psychiatric emergency room. Journal of Psychoactive Drugs. 1989;21(2):169-175. [pmid: 2760757].
Yeary, J.R., and Heck, C.L. Dual diagnosis: eating disorders and psychoactive substance dependence. Journal of Psychoactive Drugs. 1989;21(2):239-249. [pmid: 2668488].
Zweben, J.E. Issues in the treatment of the dual-diagnosis patient. In: Wallace, B., ed. The Chemically Dependent: Phases of Treatment and Recovery. New York: Brunner/Mazel, 1992.
Zweben, J.E. Counseling issues in methadone maintenance treatment. Journal of Psychoactive Drugs. 1991;23(2):177-190. [pmid: 1765891].
Zweben, J.E., and Smith, D.E. Considerations in using psychotropic medication with dual diagnosis patients in recovery. Journal of Psychoactive Drugs. 1989;21(2):221-226. [pmid: 2668486].