# Consensus Panel

Chair
- Paul D. Nagy, M.S., C.S.A.C.
- Director
- Duke Alcoholism and Addictions Program
- Clinical Associate
- Department of Psychiatry
- Duke University Medical Center
- Durham, North Carolina

Facilitators
- J.B. Bixler
- Executive Director
- Association of Community Mental
- Health Authorities of Illinois
- Springfield, Illinois
- Christine L. Kasser, M.D.
- Medical Director
- Baptist Recovery Center
- Memphis, Tennessee
- Mary E. McCaul, Ph.D.
- Director
- Comprehensive Women's Center
- Francis Scott Key Medical Center
- Johns Hopkins Hospital
- Baltimore, Maryland
- Larry G. Osmonson, N.C.A.C. II, C.A.P., C.T.R.T.
- President
- National Association of Alcoholism and Drug Abuse Counselors

Workgroup Members
- L. Worth Bolton, M.S.W., A.C.S.W.
- Program Director
- Westhaven Outpatient Treatment Programs
- Raleigh, North Carolina
- Bill B. Burnett, M.Ed.
- Director
- Treatment and Intervention
- South Carolina Commission on Alcohol and Drug Abuse
- Bruce Carruth, Ph.D., L.C.S.W.
- Private Practice
- Little Rock Psychotherapy Group
- Little Rock, Arkansas
- Doris Derrington
- Consultant
- Alcohol and Drug Abuse Services
- Topeka, Kansas
- Robert F. Forman, Ph.D.
- Executive Director
- Rehab After Work
- Fitzgerald Mercy Hospital
- King of Prussia, Pennsylvania
- Marco E. Jacome, C.S.A.D.C., C.E.A.P., N.C.A.C. II
- Executive Director
- Healthcare Alternative Systems, Inc.
- Chicago, Illinois
- Gary Q. Jorgensen, Ph.D.
- Director
- Drug and Alcohol Abuse Clinic
- School of Medicine
- University of Utah
- George Kolodner, M.D.
- Medical Director
- Kolmac Clinic
- Silver Spring, Maryland
- Jewell Oates, Ph.D.
- Executive Director
- The Women's Treatment Center
- Chicago, Illinois
- Philip Spivey, Ph.D.
- Director
- Outpatient Services
- Smithers Alcoholism Treatment and Training Center
- St. Luke's-Roosevelt Hospital
- New York, New York