# Chapter 6—Special Fiscal and Administrative Issues

Effective fiscal and administrative management helps provide a solid foundation for the delivery of clinical services. Alcohol and other drug (AOD) treatment programs often face shrinking budgets and cutbacks -- despite intense demands for improvements regarding the qualification of clinicians, quantifiable treatment outcomes, and the quality of service delivery. This has been a time of profound change with regard to health care delivery services -- for both providers and payers in private and public spheres. More change is on the horizon, such as national health care reform. While such reform seems inevitable, the specifics are yet to be determined, and the effect on AOD treatment delivery is as yet unknown. For these reasons, a few aspects of program administration warrant a brief discussion in this TIP:

- Quality improvement
- Public funding
- Private funding
- Managed care
- Program costs.

## Quality Improvement

Many people in AOD programs are familiar with the terms quality assessment and quality improvement in relation to meeting Federal and State regulations, or meeting the standards for accreditation by such organizations as the Joint Commission on Accreditation of Healthcare Organizations. In the past, the responsibility and perceived responsibility for quality assessment and improvement within an AOD treatment program was assigned to an individual who was designated as the "QA person." While it is true that program administration and clinical administration have the ultimate authority to establish policy and modify procedures regarding quality improvement, all program personnel -- clinical and nonclinical -- are responsible for quality improvement efforts at all program levels.

Indeed, the emphasis on the importance of all employees being an integral part of quality improvement is part of a sound management approach that puts significant emphasis on meeting the needs of the customer or client as an essential aspect of improving the quality of service delivery. One such management approach is called Total Quality Management (TQM). Although TQM origins are in the private business sector, it is becoming an integral component of private and public health services delivery systems. For example, the Joint Commission on Accreditation of Healthcare Organizations, an organization that has as its mission the improvement of the quality of health care, is making a purposeful shift away from describing these efforts as "quality assessment and improvement," and toward the concept of "improving organizational performance."

By doing so, they are explicitly stressing the continual improvement of health care service delivery by improving the performance of all staff members, prompting enhanced performance of the program, and resulting in improved service delivery (Joint Commission on Accreditation of Healthcare Organizations, 1993).

### A Brief Look at TQM

TQM is a focused management philosophy for providing the leadership, training, and motivation to continuously improve an organization's management and operations (Walton, 1990). The TQM approach includes several strategies and assumptions that are easily adaptable to IOT programs. These strategies include:

- Recognition of quality as the presence of value rather than the mere absence of defect
- Focusing on prevention of problems rather than merely eliminating late-stage problems
- Creation of a working environment where all employees seek continuous improvement
- Emphasizing significant cross-training and teamwork
- Focusing on the services being delivered as well as the process of providing services
- Forging a provider-customer partnership to work on improvements.

There are several key principles that are intrinsic to TQM. These include a focus on the customer, continual process improvement, communication, strategic quality planning, quality leadership, quality skills training, and quality measures. The heart and soul of TQM are the principles of continued focus on the customer and continual improvement of the process involved in providing customer products and services. These key principles can be understood as steps that form the basis of an ongoing cycle of change and improvement. When one phase of the cycle is completed, the cycle begins anew.

- Customer focus -- Irrespective of funding or setting, AOD programs provide services to various customers. Thoughtful consideration must be given to the idea of what constitutes a customer for an AOD treatment program. Indeed, it is critical to identify all the customers in the system. While patients are one obvious type of customer, there are others, including referral sources, family members, employers, funding sources, and other providers. Central to the TQM approach is a constant emphasis on satisfying the needs of the customer and identifying ways that can best meet those needs. Importantly, there should be an understanding of the strengths and weaknesses in the system from the customer's perspective, and involvement of the customer in problem solving.
- Continuous process improvement -- Service delivery involves products and processes. Products are the things that are provided to a client, including treatment services. Processes include everything that is done to provide the client with the products and services. Programs that are actively involved with making quality improvements must focus on both products and processes and continual improvements. The emphasis is on improvement, not compliance with existing structures. The goal is to reduce chronic waste of time, labor, material, and funds. Often this involves the identification and analysis of critical processes and the simplification and removal of variation.
- Communication -- The TQM approach recognizes that the individuals who are actually performing certain jobs are the best sources for identifying improvement opportunities for those job functions. Thus, to encourage program-wide participation, all staff, including administrators, must share information and experiences continually. This can be accomplished through newsletters, suggestion boxes, teamwork days, meetings, and other events.
- Strategic quality planning -- Critical to TQM is having a vision or mental image of a future state where the quality of service delivery always elicits satisfaction. A goal is a statement of attainable achievement that can be proposed and accomplished with sustained effort and energy over a given length of time. Specific vision statements help program staff to identify the kind of future that is preferred for the program. Setting quality goals helps motivate employees and promotes teamwork. In order to achieve quality goals, programs must be committed and must communicate that commitment to all staff members. An initial step is to formalize the organizational planning process. Quality plans include such elements as mission, goals, measurable objectives, vision, customer identification, quality policies, management principles, benefits, expectations, external and internal measures, role of quality assurance, and productivity initiatives. Through employee committees, documentation, and constant communication, the plan becomes a part of the day-to-day operations and the culture of the organization.
- Quality leadership -- Program leaders (both administrators and program staff) have critical roles in the development of quality within their programs. They help provide a focus on the patient. They can support and encourage all staff to participate in quality improvement and install structures, such as task forces and steering committees, and allocate resources. They become role models and nonverbally communicate their commitment to quality by directing their attention to promotion of quality. As previously mentioned, employees who perform certain tasks are often the best sources for identifying improvement opportunities for those tasks. Since such staff members may not have great stature in the formal hierarchy, it is essential that staff members become empowered by administrators and management. In this way, anyone can assume leadership roles within the program.
- Quality skills training -- TQM involves a plan for providing training about quality in order for employees to achieve quality goals and objectives. Ultimately, all staff should be trained in the tools and techniques of TQM. Staff training should include such topics as quality principles and concepts, continuous process involvement, problem solving, setting measurable objectives (benchmarking), working in teams, managing in a participative environment, evaluating outcomes, and communications.
- Quality measures -- In order to identify opportunities for quality improvement, programs must assess where their strengths lie. This can be done through regular assessment processes that check for compliance with Federal or State laws or accreditation requirements. This can also be accomplished through patient feedback, questionnaires, focus groups, and other practices. But the focus of TQM is on the utilization of quality measures. Measures may be utilized throughout an organization to provide feedback on a regular basis regarding the degree to which the program is meeting its quality goals, objectives, and standards. An array of methods may be used to simplify data collection and statistical analysis and develop useful, reliable information that serves as a real-world scorecard. These may include client surveys, benchmarking, statistical process control, work flow analysis, and cost of quality measures.

These measures are not limited to providing care, but can also be applied with regard to such problems as waiting lists. From the perspective of TQM, waiting lists relate to customer satisfaction issues: patient discontent based on the inaccessibility of treatment services. Thus, TQM would approach the subject of waiting lists in an ongoing, revolving cycle of improvement, in this case, continually making improvements that result in shorter waiting lists.

Key Principles of Total Quality Management

- Customer focus
- Continual process improvement
- Communication
- Strategic quality planning
- Quality leadership
- Quality skills training
- Quality measures

Quality improvement is an essential aspect of IOT programming. TQM practices can be easily adapted to the IOT program environment and can have a tremendous impact with regard to improving AOD treatment. TQM projects have been used in the IOT setting for such purposes as the following:

- Analyzing treatment planning and continuity of care issues that arise in IOT from the widespread use of outside agencies to address a range of medical, psychiatric, and psychosocial issues of program clients
- Examining defined interdisciplinary problems and issues and establishing problem-solving groups across the different disciplines when integrated services are delivered within the IOT setting.

### Permanent Program Mechanisms for Quality Improvement

All IOT programs should adhere to the following quality improvement guidelines.

- Staff should continually look for opportunities for improvement within the service delivery area, focusing on defining the breadth of customers served by the program. While the patient is the most obvious customer, staff should consider referral sources, funding sources, ancillary care providers, employers, and family members as customers to whom services are provided.
- IOT staff should measure the effectiveness of the IOT program based on such program variables as the length of client retention, the level of patient participation, and the frequency and patterns of attendance. Also, they should monitor patient information, including discharge status and program completion, patient relapse, and return to treatment.

For some evening IOT programs, involvement in quality improvement efforts can be challenging regarding the issue of using part-time contract staff as group therapists. Such staff may be present in the program only during hours when full-time, permanent staff are not available, creating potential communication problems between the two groups. One strategy for involving part-time staff in the quality improvement process is to have them cofacilitate therapy groups with a member of the full-time core staff and/or establish a regular channel for communication and feedback, such as regularly scheduled meetings, phone calls, or written communication logs.

- Programs should conduct customer surveys to obtain direct feedback on program strengths and weaknesses and recommendations for improvement from clients, referral sources, family members, funding sources, and other programs.
- Programs should gather data to help State programs accurately determine what variables will help predict whether an AOD abuser will stay in IOT care or will progress therapeutically. For example, programs can compare baseline assessments of clients who complete treatment with the assessments of clients who do not complete treatment.
- In IOT outcome evaluations, it is important to include all program participants, including those who have dropped out of treatment. Also, in a State system, which has many types of treatment programs, cross-program comparisons can be made when it is impossible to make random assignment.
- The examination of administrative issues should not be avoided when IOT practices are evaluated. There should be adequate resources allocated to administrative needs, including continuous quality improvement.

### Outcome Measures

Evaluation of program outcome is a very effective way of obtaining the information needed to improve some aspects of the quality of the program. IOT programs can incorporate outcome evaluations in relation to ongoing clinical work and patient improvement. IOT programs must establish and clarify program goals and objectives in order to conduct an outcome analysis, and to know the meaningful outcome indicators.

Moreover, outcome data should be used not only to determine whether the IOT program is doing a "good" or "bad" job, but also to interpret the nuances. For instance, when looking at AOD use among clients, a complete picture of the overall program impact on the client is needed, including general psychosocial and quality-of-life indicators. A considerable amount of data can be examined without sophisticated statistical analysis. For instance, IOT programs should be able to examine program attendance and patient outcome data and be able to readily apply findings to the program evaluation processes. An appropriate management information system should be implemented to ensure rapid and complete access to outcome data.

A variety of outcome measures are needed, including staff and administrative measures, special population measures, general treatment population measures, and treatment services.

Staff and administrative measures. Staff and administrative measures clarify outcomes by holding staff responsible for particular program components and by making them active participants in the ongoing processes of the program. Using program evaluations, staff turnover rates should be examined in different IOT programs as a measure of the level of staff satisfaction. However, when making a decision regarding program philosophy, caution should be used regarding how the staffing satisfaction data are used. Occasionally, program changes that foster superior client care can precipitate initial discomfort and resistance among program staff.

Special population measures. It is important to emphasize that program and patient outcome indicators will be different for different treatment groups. For instance, clients with dual disorders may have a different threshold for attendance than AOD patients without dual disorders. Additional outcomes that are meaningful with this group include medication compliance, psychiatric symptom improvement, and rehospitalization. Similarly, special outcome indicators may be appropriate for pregnant IOT clients including delivery complications and birth outcomes for infants.

General treatment population measures. A useful outcome measurement tool is the Addiction Severity Index (ASI) (McLellan et al., 1980; 1985; 1992a). The ASI can be administered at IOT intake and discharge by trained assessment staff members. Used at intake, it leads logically to treatment planning. At discharge, it yields specific outcome data in seven key areas of the client's life, including recent AOD use and legal, occupational, medical, family/social, and psychiatric status.

The ASI provides IOT programs with:

- A subjective patient evaluation and an interviewer evaluation of problem severity, both of which can provide an indication of patient treatment priorities.
- An easy monitoring tool for clinical supervision since severity scores in each domain can be quickly checked to ensure adequate treatment planning in problem areas.
- The capability to monitor outcomes of discharged clients through community followup. (Patients can be located and reevaluated using the ASI followup interview.)
- A research tool structured to derive objective and subjective measures of need and improvement.
- A rich database by which such issues as the relationship between client characteristics and outcome data can be examined.
- A standardized assessment instrument that permits comparisons across programs and levels of care.

Treatment Services Review. The Treatment Services Review was developed to complement the ASI and corresponds directly to ASI categories (McLellan et al., 1992). This instrument provides a structured way of measuring patient perception of the quantity of services received in each of the seven ASI areas. That is, it yields a perceived services-delivered rating. Other important measures of patient-level service delivery include: number of individual counseling sessions, number of group counseling sessions, number of urine tests and Breathalyzer checks, and length of stay.

Other measures. IOT programs also should conduct client satisfaction surveys as an evaluation tool. Self-help group involvement is another way of measuring continued sobriety and determination to retain or regain any short-term loss of sobriety.

One measure of particular relevance to the IOT setting is the successful transfer and retention of clients in long-term standard outpatient services following completion of the IOT program. Patient follow-through with the transition plan should be automatic. A primary goal of IOT services should be to motivate clients to remain in ongoing recovery programs.

### External Evaluation Processes

A number of institutionalized review processes provide useful feedback for IOT programs, including:

- Accreditation organizations -- Often, State accreditation processes, such as licensing or certification divisions, as well as national accreditation bodies, such as the Joint Commission on Accreditation of Healthcare Organizations, or the Commission on Accreditation of Rehabilitation Facilities, provide a readily available, and often mandated, source of quality improvement.
- Consultants -- IOT administrators may find it helpful to seek professional assistance in defining and clarifying their program mission. Consultants can be particularly helpful with respect to program development, preparing mission statements, stating program philosophies, and translating all of these into procedural policy. Consultants can not only help programs establish and plan TQM programs, they can also "sell" the importance of the TQM process to staff members by conducting staff presentations on TQM.
- Governing board -- Whether by choice or because of State regulations, many IOT programs have advisory and/or governing bodies that oversee the development and operations of the program. Members of such governing bodies should have familiarity with AOD treatment and should have ample time to be actively involved. Governing board members should see their role as working in a complementary relationship with the program staff with the common goal of overall success of the program.

A clear mission statement helps make the program direction explicit and realistic. It also helps decrease the tendency of programs to overextend themselves by offering services or treating client populations that are outside their intended mission.

### Therapeutic Setting

The appearance of the facility sends a powerful message to IOT clients about dignity and respect. The appearance of the facility can have an impact on patients' assessment of program quality. IOT programs should consider the following recommendations:

- Plan ahead for flexibility regarding treatment team and group space. Maximize the flexibility of available space. When designing a new facility, first evolve an understanding of space needs in order to custom-design the space for most efficient use.
- Keep furniture and facility resources in good working order. The physical surroundings should be clean and tidy.
- Design a space for clients to get away from the therapy rooms during breaks in treatment. Clients need a physical break from the intensive sessions. Space itself can be therapeutic.
- Many IOT programs will want to provide refreshments, and a dining room or cafeteria area is ideal. At the least, a snack machine and coffee should be available.
- For some treatment groups, particularly large urban programs serving a homeless population, shower and laundry facilities will make the IOT program more attractive.
- Certain literature and didactic information should be available. Updated self-help meeting schedules should be present in high-traffic areas such as the clinic lobby.
- Bathrooms should be conveniently located near group therapy rooms and recreational space. Also, the bathrooms should be designed with the need for collection of urine samples for drug screening in mind. Alternatives include one-way mirrors, space for direct observation, and the ability to temporarily turn off the water supply.
- Whenever possible, IOT programs -- especially those with extended hours -- should have a recreation room for patients. These areas should be designed to promote client socialization.
- Each IOT program has to thoughtfully address its smoking policy. This is both a facility and a program philosophy issue. If smoking is allowed internally, make sure the rights of nonsmokers are protected.
- A centralized entrance for client registration may be useful, depending on the particular client groups and setting. This has the added benefit of monitoring who is coming in and out of the program.
- The neighborhood setting is important. While programs should be located in the areas where the target patients reside, the program also should be in a safe location, and be secure. Patients and staff should feel safe participating in treatment, especially in evening programs. Consideration should be given to the level of acceptance that the neighborhood has for the program. Efforts should be made to ensure as cooperative and supportive arrangements as possible.

## Public Funding

For most States, the amounts of fiscal support from general revenue and Federal block grants have been inadequate to finance the level of services demanded by the public. Major grant funds, for example, have been used to provide treatment to high-risk youth, women and children, and intravenous drug users. Fortunately, block grant requirements do not restrict the eligibility of any particular types or models of programs. Hence, AOD treatment programs that are based on the intensive outpatient treatment (IOT) level of care are eligible for block grant funds.

Since the States have a fair amount of discretion about the use of block grant funds, they often seek programs that will make effective use of existing monies. One such strategy is to identify specific groups for which State money can be targeted and for which IOT programs can be created. For example, IOT programs may be created to treat such specific groups as intravenous drug users, adolescents, clients with dual disorders, incarcerated offenders, and women and their infants and children. Targeting services to these groups may also help States meet certain Federal block grant requirements, such as the current requirements to give treatment preference to pregnant drug users.

Unfortunately, however, when IOT programs are designed to provide care for narrowly targeted groups, their ability to provide care for the general population of addicted people may be restricted. This means they will be unable to treat many people who require the type of treatment provided by IOT programs. Thus, program planners need to balance these concerns, utilize creative strategies, and identify strategies and additional sources of funding that will permit the broadening of services.

Alternative sources of public funding are available to establish and maintain IOT programs. These sources include funds allocated by Federal or State programs in criminal justice, AIDS, maternal and child health, and mental health and demonstration and set-aside funds from the Center for Substance Abuse Treatment (CSAT) and the Center for Substance Abuse Prevention (CSAP). For example, CSAT, CSAP, the National Institute on Alcohol Abuse and Alcoholism, and the National Institute on Drug Abuse have supported demonstration projects targeting several specific groups, such as the homeless, pregnant women, and women of childbearing age. These projects, awarded competitively, offer excellent opportunities for innovative programming with an emphasis on a comprehensive continuum of services.

The amount of State funds available to support AOD abuse treatment programs varies widely among the States. Program managers and staff should aggressively seek out and identify potential sources of State funds, and improve the skills required to write and submit grant applications. IOT programs are in especially good positions to develop creative alliances with other treatment providers and submit joint grant applications when permissible.

At this time, Medicaid is an important funding source for providing AOD treatment based in IOT programs. IOT program administrators should be fully informed about State regulations governing the use of Medicaid funds. Some States, for example, may attempt to ensure equitable distribution by granting programs specific amounts of Medicaid and State-match funds. Some programs may not use their full allocation, and the balance can be used by other programs that need more funds. This requires administrators to have a full understanding of the State's procedures and regulations for Medicaid granting and matching. In some cases, where experience has shown that certain programs are able to attract more Medicaid clients than others, the State will arrange for them to bill beyond the amount of their individual grant, as long as the State's pool of Medicaid funds is not exhausted.

In some situations, Medicaid will pay half the cost for treating individuals under age 17. A major problem with Medicaid is that many States do not provide Medicaid coverage for males who are not chronically ill or elderly. At intake it is important to ask men if they have custody of children. If they do, they are probably eligible for Medicaid coverage themselves.

Another creative alternative is a partnership between health maintenance organizations (HMOs) and managed care businesses to provide IOT coverage. A special program can be developed so that patients served by these plans can receive targeted treatment services that conform to their benefits.

In some instances, counties have developed their own managed care programs or even created their own IOT programs -- such as adolescent IOT programs -- which are funded entirely with county taxes. Programs may be able to draw on local, county, or township taxes. This approach saves the jurisdiction from having to pay out-of-county treatment providers for inpatient care. Similarly, some very large employers have developed their own IOT programs for AOD problems among employees.

In many cases, IOT services can be added to existing residential treatment programs. However, there is a risk that allocating funds for an IOT level of care may actually diminish the available funds for the residential treatment program. Sometimes, when the inpatient facility is reimbursed on a fee-for-service basis, the outpatient programs may be misused as a feeder to the inpatient program.

However, IOT can be combined with residential care in the same program to maximize the opportunity for patient-placement matching, enhance the continuum of care, and reduce the overall cost of AOD treatment services. Some clients require a period of residential stabilization before they can successfully take part in IOT. If admitted directly to IOT, they may relapse. The duration of residential care needed can vary greatly from patient to patient, and must be tailored to individual patients' rates of improvement. However, the goal should be to transition clients to the least restrictive level of care as soon as possible.

The development of State regulations defining and governing IOT programs is a critical step in the recognition and reimbursement of individual programs. As States develop a licensure or regulatory category for this level of care, IOT programs can more easily receive reimbursement.

## Private Funding

Benefit structures are underdeveloped in relation to the reimbursement of IOT by private payers. While reimbursement strategies have been developed for inpatient AOD abuse treatment, many third-party payers have not developed any or adequate reimbursement strategies for the IOT level of care.

It is critical for programs that provide or intend to provide IOT services to establish an ongoing dialogue with major payers. Indeed, this dialogue should begin prior to opening an IOT program. This will diminish or possibly eliminate surprises and problems related to reimbursement and clinical issues.

Specifically, third-party payers should be given the opportunity to provide input into the development of reimbursement strategies and should be invited to join with the program as partners in providing quality intensive outpatient treatment.

To enhance cooperation with payers, IOT program providers should pursue and obtain the accreditation, licensing, and certifications that the payers recommend or require. Certifications cannot usually be obtained before a program is operational. These may include Joint Commission on Accreditation of Healthcare Organizations, Commission on Accreditation of Rehabilitation Facilities, and State accreditation.

### Suggestions for Providers

- Providers should create and maintain a database related to services that the various payers will reimburse. This database should include: payers (insurer's name, phone number, address, contact people) and information regarding deductibles, copayments, daily rates, capitation (maximum payments), and billing procedures. A tracking mechanism should be included to specify recertification requirements when they exist.
- Providers should meet in person with the reviewers and decisionmakers who approve admissions. By so doing, the provider and payer can have a clear understanding of each other's expectations, practices, and policies. For example, there should be a clear understanding regarding what constitutes a treatment day and how nontreatment days are to be considered.
- Providers should obtain written copies of payers' policies and guidelines for billing and payment, and not rely solely on phone conversations.
- In situations where payers will not furnish providers with written policies and procedures, the provider should send a confirming followup letter or fax memorandum that summarizes the content of a conversation or phone call. Written documentation of informal understandings and agreements can save much money, time, and frustration.
- Payers are increasingly requiring outcome data for reimbursable treatment services. Thus, providers should collect outcome data, so that they can demonstrate quality treatment and quality improvement. Often such data can be gathered at little or no cost by using graduate students or trained support staff to collect followup client information.
- Providers should inform payers that research suggests that for some patients, IOT provides a level of care equivalent to inpatient treatment. This is not true for nonintensive outpatient treatment (Fink et al., 1985). Therefore, careful patient-treatment matching is needed to ensure that clients are placed in the least restrictive and most cost-effective type of treatment program, based on the severity of their presenting AOD use problem, medical and psychiatric status, and psychosocial conditions. Providers should provide payers with admission criteria that distinguish IOT patients from patients that can be served by lower intensity outpatient services. Further, IOT programs should ensure that the level of care offered is clearly distinct from that available in nonintensive outpatient programs?
- Providers should inform payers that IOT has an important place in continuing care, since the longer clients remain in outpatient treatment, the higher is the likelihood of a more stable recovery (McCaul and Svikis, 1991).
- When communicating with payers, providers should clearly and carefully describe the specific types, intensity, range, and levels of IOT services that are provided to help payers make informed and educated decisions.
- Providers should establish assertive, close, and ongoing linkages to social service organizations and health care programs that offer other types and levels of care with the greatest cost effectiveness, if services are not provided inhouse.
- During the intake phase of IOT treatment, it is useful to identify whether the client may have additional reimbursement coverage through a spouse's or other family member's insurance policy. Sometimes, despite a client's own exhausted benefits, coverage may be obtained through a secondary payer.

Some payers may regard IOT as an add-on or optional service. It is the responsibility of IOT treatment providers to educate payers that IOT is a specific level of care that can provide a level of treatment intensity that approaches medically monitored inpatient treatment but is achieved in an outpatient setting. Importantly, payers should understand that IOT is a vital part of the continuum of care that includes: 1) medically managed inpatient treatment, 2) medically monitored inpatient treatment, 3) intensive outpatient treatment, and 4) outpatient treatment. Payers should also be educated that IOT is a level of care, not a specific type or model of program. For example, payers should be taught that IOT can be adapted to several models such as day treatment, evening treatment, weekend treatment, partial hospitalization, and treatment in combination with housing such as apartments, dormitories, or other forms of resident housing.

Providers and payers should understand that moving clients from one level of care to a less intense level of care (such as from inpatient care to IOT) will utilize the continuum of care, decrease daily treatment costs, and make it possible to provide prolonged episodes of treatment. However, it is imperative for providers to remind payers that the decisions to move clients from one level of care to another should always be based on the individual client's treatment needs.

In some cases, where payers do not yet have a policy regarding insurance policy conversion from inpatient to outpatient treatment, they may not be able to guarantee this service. However, individual insurance company staff may be able to informally provide such a conversion. In any case, informed agreements should be in writing to avoid misunderstandings that may occur later. There is an increased likelihood for such flexibility when effective, proactive, and ongoing communication and collaboration exists between providers and payers.

There is a need for IOT programs to collaborate with one another in lobbying efforts. Organized National, State, and local institutions can help educate legislators, as well as payers, regarding the benefits of IOT and demonstrate their support for particular payer reimbursement strategies. Professionals from employee assistance programs can work with benefits departments to explain the utility of IOT programs

## Managed Care

It is clear that the process of reforming America's health care delivery system is under way. However, it is less clear what the final health care reform package will look like. Also, it is unknown how the new system will affect AOD treatment, mental health services, and Medicaid. In fact, once negotiations are complete and new laws have been established, it is likely that new health care reform policies will be phased in over several years. It is likely that several years will pass before the ultimate effects on AOD treatment and mental health are thoroughly understood. Understandably, and often because of poor experiences with some managed care companies, AOD treatment program administrators are apprehensive about the potential negative effects of a national health care system that incorporates managed care and managed competition.

In existing managed care programs, problems may arise regarding the patient's right to confidentiality in seeking AOD treatment. In managed care settings, patients typically seek initial help from an employee assistance program professional or their managed care provider physician or case worker who then makes the appropriate recommendations and referrals. However, managed care provider physician records are not protected under the Federal confidentiality regulations governing AOD treatment programs. Thus, managed care provider physician records are subject to more liberal disclosure. As a consequence, patient information is not strictly protected in the same way as records in AOD treatment programs.

Clients may not want the managed care provider to reveal to anyone else that they have an AOD abuse problem. Authorization for AOD treatment would require clients to disclose their AOD status to their managed care provider. This is an issue that some States are beginning to address and regulate.

Under managed care models, a capitated agreement -- or at-risk contract -- may be an integral component of providing care. This capitated agreement involves the payment of a monthly or annual flat fee to a treatment provider who agrees to provide a specified range of services to all clients covered by the contract who seek treatment. In effect, to be ensured of regular payments, the provider accepts the risk for delivery of services. In such agreements, the provider should be particularly careful to determine utilization rate histories for the particular geographic areas being served. These rates vary greatly and can have a dramatic impact on costs. For example, utilization rates can range from one to six patients per 1,000 population seeking treatment -- a sixfold range!

Providers that choose to become involved with capitated agreements should request and obtain a utilization rate history. In other words, the provider should have an understanding of the number of people or the percentage of the program's base group that are expected to seek care each year. Similarly, the provider should carefully consider the implications associated with taking the risk for all AOD treatment needs -- which may include detoxification, and inpatient and outpatient treatment -- compared with a capitated agreement that requires only the delivery of IOT and outpatient treatment.

Although the cost of managing care for IOT is less expensive to develop and operate than the cost for many other conditions, it is not inexpensive. Indeed, comprehensive AOD treatment involves attending to medical, psychiatric, and AOD problems that require sophisticated clinical interventions. These interventions require the use of licensed, credentialed, and certified professionals.

## Program Costs

Very little data exist on IOT program costs. Although less expensive to operate than inpatient treatment, good IOT programs are not generally inexpensive. Also, they have more difficulty than inpatient programs in generating significant profit margins even when efficiently organized and managed.

The consensus panel obtained data on total expenses and total revenues from six different day or evening IOT treatment programs, in the northeast, Midwest, and southern part of the Nation in rural, urban, and suburban areas. The programs have various payer mixes, including insurance, managed care, Medicaid, Medicare, HMO contract, State grant or purchase of care, and self-pay. Also represented were private nonprofit and for-profit programs as well as a public program, with a variety of client capacities and salary ranges. These data are provided in Exhibit 6-1.

Exhibit 6-1 Intensive Outpatient Treatment (IOT) Programs: Sample Cost Data

Intensive Outpatient Treatment (IOT) Programs: Sample Cost Data
| 1 | 2 | 3 | 4 | 5 | 6
Program Type
Evening | X | X | X | X | X | X
Day | X | X | | X | X
Partial hospitalization | | | | X | | X
Other | Aftercare | | | | Adolescent ^2^
Region | NE | Midwest | South | NE | South | NE
Locale | Urban | Urban | Small metro. | Urban | Urban/rural | Urban/suburban
Institutional Status
Private for-profit | | | | | | X
Private nonprofit | X | X | X | X | X
Public | | | | | X
Payer Mix (by %)
Insurance/managed care | 45% | X ^1^ | 75% | 1% | | 50%
Medicaid | | X ^1^ | | 68% | 5%
Medicare | | X ^1^ | 3% | 2%
Self-pay | 5% | X ^1^ | 22% | 1% | | 10%
HMO contract | 50% | X ^1^ | | | | 40%
State grant/purchase of care | | X ^1^ | | 28% | 95%
Capacity (at 100%)
Daily | 150 ^3^ | 64 | 24 | 24 Full ^4^ 20 Partial ^4^ | N/A ^5^ | 48
Weekly | 300 ^3^ | 320 | 24 | 24 Full ^4^ 20 Partial ^4^ | N/A ^5^ | 100 (240 in aftercare)
Salary Ranges
Administrators/managers | $38,000 ^6^ to 50,000 | $30,000 to 52,000 | $35,000 to 50,000 | $26,000 to 67,000 | N/A | $45,000
Physicians | $70/hour to 100/hour | $30,000 to 50,000 | $20,000 ^7^ to 26,000 | $26.50/ hour | N/A | $36,000 for 1/3 time
Social workers | $28,000 to 35,000 | $30,000 to 37,000 | $28,000 to 35,000 | $24,700 ^8^ to 28,200 ^8^ | N/A | $30,000 to 45,000
Psychologists | $30,000 to 40,000 | N/A | $35,000 to 45,000 | Only program director | N/A | N/A
Support staff | $22,000 to 28,000 | $13,000 to 23,000 | $18,000 to 25,000 | $14,300 to 20,000 | N/A | $19,000 to 25,000
Other | N/A | Addiction counselor $20,000 to 30,000 | Substance abuse counselor $23,000 to 35,000 | Substance abuse counselor ^9^ $18,000 to 23,200 | N/A | Counselor $22,000 to 28,000
Other | N/A | Addiction counselor $20,000 to 30,000 | Substance abuse counselor $23,000 to 35,000 | Nursing (LPN) $25,000 to 28,000 | N/A | Counselor $22,000 to 28,000
Other Expenses (by %)
Administrative overhead | 18% | 12% | 7.1% | N/A | N/A | 16%
Personnel (including fringe) | 72% | 78% | 80.5% | N/A | N/A | 75%
Facility costs | 10% ^10^ | 10% | 12.4% | N/A | N/A | 9% (rent)
Total Expenses Total Revenues
| FY 91-92 | | FY 91-92
Program 1 | $1,023,679 | | $1,157,208
Program 2 | $2,033,287 | | $2,025,504
Program 3 | $267,440 | | $364,726
Program 4 | $187,106 Full day $82,756 Partial day | | $254,561 Full day $111,832 Partial day
Program 5 | $2,623,332 | | N/A
Program 6 | $1,120,000 | | $1,140,000

1 Payer mix includes all categories; percentages not provided.

2 Ten adult programs and four adolescent programs.

3 In total of three centers

4 Full day = 2-week program; Partial day = 4-week progra

5 19 adult, 4 adolescent programs with >3,000 patients

6 Executive director's salary is in a management contract and is $70,000 for management.

7 Part-time, 10 hours

8 Master's-level substance abuse therapist; various disciplines

9 Bachelor's-level clinician with AOD credentials

10 Includes center directors and marketing budget. Directors provide some direct service.